# Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and KQs for this review. The analytic framework illustrates the KQs that guided the review (Figure 1).

Figure 1 Analytic Framework

Abbreviations: CAS = carotid artery stenosis; CAAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; KQ = key question.

The framework begins on the left with our patient population of interest: asymptomatic adults. A horizontal arrow with the word “KQ 2” goes from the population to text that reads “Risk of CAS 60%-99%” with 3 levels listed: A, decreased; B, average; C, increased. Continuing to the right, a horizontal arrow labeled “KQ 3” connects the “Risk of CAS” text to a box containing the words “CAS 60%-99%.” Above the KQ 3 arrow are the words “Screening plus or minus confirmatory tests.” A curvy arrow labeled “KQ 7” descends from the “pharmacotherapy” arrow to an elliptical shape with the words “harms of screening/confirmatory tests” to illustrate the focus of KQ 7. From the “CAS 60%-99%” box, an arrow labeled KQ 4 goes to the right and connects to a box labeled “Risk of ipsilateral stroke or harms: A, decreased; B, average; C, increased.” From the “Risk of ipsilateral stroke or harms” box, an arrow going to the right connects to a box labeled “Reduced number of ipsilateral strokes/deaths.” The arrow is labeled KQs 5, 6 and the word “Treatment” appears above it. A curvy arrow labeled “KQ 8” descends from the “Treatment” arrow to an elliptical shape with the words “harms of CEA or CAAS” to illustrate the focus of KQ 8. An arrow labeled “KQ 1” connects “Screening plus or minus confirmatory tests” to “Reduced number of ipsilateral strokes/deaths.”

### Key Questions

1 Is there direct evidence that screening adults with duplex ultrasonography, CTA, and/or MRA for asymptomatic CAS reduces fatal or nonfatal ipsilateral stroke?
  a. Is there direct evidence for persons at decreased risk?
  b. Is there direct evidence for persons at average risk?
  c. Is there direct evidence for persons at increased risk?
  d. Does the evidence differ for subgroups defined by age, sex, race, or ethnicity?
2 Are externally validated, reliable risk stratification tools available that distinguish persons who are more or less likely to have CAS (defined as 60% to 99% stenosis)?
3a What is the accuracy and reliability of screening with duplex ultrasonography, used alone or followed by CTA or MRA, to detect potentially clinically important CAS (defined as 60% to 99% stenosis)?
3b Do the accuracy and reliability differ for subgroups defined by age, sex, race, or ethnicity?
4a Are externally validated, reliable risk stratification tools available that distinguish persons with asymptomatic CAS (defined as 60% to 99% stenosis) who are at decreased or increased risk for ipsilateral stroke caused by CAS?
4b Are externally validated, reliable risk stratification tools available that distinguish persons with asymptomatic CAS who are at decreased or increased risk for harms from CEA or CAAS?
5 For persons with asymptomatic CAS (defined as 60% to 99% stenosis), does intervention with carotid endarterectomy (CEA) or carotid angioplasty and stenting (CAAS) provide incremental benefit beyond current standard medical therapy for reduction of fatal or nonfatal ipsilateral stroke?
  a. Is there incremental benefit for persons at decreased risk for ipsilateral stroke caused by CAS?
  b. Is there incremental benefit for persons at average risk for ipsilateral stroke caused by CAS?
  c. Is there incremental benefit for persons at increased risk for ipsilateral stroke caused by CAS?
  d. Does the evidence differ for subgroups defined by age, sex, race, or ethnicity?
6 For persons with asymptomatic CAS (defined as 60% to 99% stenosis), does the addition of medications (e.g., aspirin, statins) provide incremental benefit beyond current standard medical therapy that includes treatment of traditional risk factors (e.g., hypertension, hypercholesterolemia) for reduction of fatal or nonfatal ipsilateral stroke?
  a. Is there incremental benefit for persons at decreased risk for ipsilateral stroke caused by CAS?
  b. Is there incremental benefit for persons at average risk for ipsilateral stroke caused by CAS?
  c. Is there incremental benefit for persons at increased risk for ipsilateral stroke caused by CAS?
  d. Does the evidence differ for subgroups defined by age, sex, race, or ethnicity?
7a What are the harms associated with screening or confirmatory testing for asymptomatic CAS?
7b Do the harms differ for subgroups defined by age, sex, race, or ethnicity?
7c Do the harms differ for subgroups defined by comorbidities?
8a What are the harms associated with CEA or CAAS for the treatment of asymptomatic CAS?
8b Do the harms differ for subgroups defined by age, sex, race, or ethnicity?
8c Do the harms differ for subgroups defined by comorbidities?

### Contextual Questions

We addressed the following contextual question: What is the accuracy and reliability of auscultation for carotid bruit to detect potentially clinically important CAS (60% to 99% stenosis)?

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and EMBASE for English-language articles published through September 2013. We conducted a targeted update search for trials published through March 31, 2014, limited to MEDLINE. We used Medical Subject Headings (MeSH) as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, the Cochrane Stroke Group Trials Registry, and the World Health Organization International Clinical Trials Registry Platform (WHO ICTRP). To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies that met our inclusion criteria and added all previously unidentified relevant articles. We reviewed all literature suggested by peer reviewers or public comment respondents and, if appropriate, incorporated it into the final review.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs27 (Appendix B Table 1). We included studies focused on asymptomatic adults with CAS, but also included studies that enrolled both symptomatic and asymptomatic subjects if the asymptomatic group was analyzed separately. For the population of interest, we did not rigidly consider persons with 60 to 99 percent CAS as a single homogeneous cohort. Rather, we included studies enrolling subjects that went beyond that degree of CAS (e.g., VACS [Veterans Affairs Cooperative Study] allowed enrollment of persons with 50% to 99% CAS), and we evaluated the available evidence for subgroups in that cohort. For example, we evaluated evidence for persons with 80 to 99 percent CAS, if available. For KQ 1, we searched for randomized, controlled trials (RCTs) comparing screened with nonscreened groups. For KQ 2, we included studies that developed risk stratification tools, and then validated the tools using an external population. For KQ 3, we focused on systematic reviews, but also included primary studies that were published after the included systematic reviews. For KQ 4, we searched for cohort studies that developed risk stratification tools, and then validated the tools using an external population. We required studies to follow a cohort of adults with asymptomatic CAS to develop a tool predicting risk for ipsilateral stroke (KQ 4a) or periprocedural harms (KQ 4b). For both KQ 2 and KQ 4, we required that risk stratification tools (or “risk prediction tools”) combined multiple variables and allowed us to calculate risk for individual patients. Risk stratification tools may include clinical factors (e.g., age, diabetes) and anatomic or imaging predictors (e.g., plaque area or morphology, silent embolic events, contralateral disease). For KQ 5, we included systematic reviews and RCTs comparing CEA or CAAS with medical treatment. For KQ 6, we searched for systematic reviews and RCTs that compared the addition of one or more medications to current standard medical therapy (including treatment of traditional risk factors) with the addition of placebo to current standard medical therapy (including treatment of traditional risk factors). For KQs 7 and 8, we included systematic reviews, multi-institution trials, or cohort studies (including registries) reporting rates of relevant harms.

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Then, two investigators independently reviewed the full texts to determine final inclusion or exclusion. Disagreements were resolved by an experienced team member.

## Quality Assessment and Data Abstraction

We extracted pertinent information from each article, including information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor using predefined criteria (Appendix D).28 Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each key question by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance.29 We qualitatively assessed the populations, interventions, comparators, outcomes, and study designs of the included studies, looking for similarities and differences.

We conducted quantitative synthesis of RCTs comparing CEA with medical therapy using meta-analyses of relevant outcomes reported by multiple studies. We used random-effects models (DerSimonian and Laird) using the inverse-variance weighted method to estimate pooled effects.30 We calculated risk differences between groups to reflect the absolute difference between CEA and medical therapy. We calculated rates using the number of all randomized patients as the denominator to reflect a true intention-to-treat analysis. For ACAS (Asymptomatic Carotid Atherosclerosis Study), we used the actual observed numbers of events (reported for median followup of 2.7 years) rather than the projected/estimated 5-year rates.31 For ACST, we used complete data from the 10-year publication.32

We conducted quantitative synthesis of composite outcomes that included key benefits and harms and that were the primary outcomes in ACAS and ACST (Asymptomatic Carotid Surgery Trial): 1) perioperative stroke or death (within 30 days) and subsequent ipsilateral stroke and 2) perioperative stroke or death (within 30 days) and any subsequent stroke. We also conducted quantitative synthesis for the following outcomes assessing potential benefits and harms: all-cause mortality, any stroke or death, ipsilateral nonperioperative stroke (i.e., occurring after the perioperative period), any nonperioperative stroke, perioperative stroke or death, and perioperative myocardial infarction.

To allow some comparison of rates of perioperative harms reported in RCTs with those from sources that may be more representative of real-world clinical practice, we conducted meta-analyses of noncomparative cohort studies (including registries) reporting perioperative (30-day) stroke or death rates. We also conducted meta-analyses of perioperative stroke or death rates reported in trials involving CEA or CAAS, regardless of the comparator. We analyzed rates for CEA and CAAS separately. When articles did not report 95 percent confidence intervals for rates of perioperative stroke or death, we calculated 95 percent confidence intervals using the Wilson method.33 Random-effects models were used to estimate pooled event rates.

The chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess statistical heterogeneity in effects between studies.34,35 An I^2^ from 0 to 40 percent might not be important, 30 percent to 60 percent may represent moderate heterogeneity, 50 percent to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.36 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p value from the chi-squared test or a confidence interval for I^2^).

We conducted several types of sensitivity analyses. First, because DerSimonian and Laird random-effects models may not perform well for small meta-analyses (when few studies are included), we conducted sensitivity analyses using profile likelihood random-effects methods.37-40 Results for profile likelihood meta-analyses were essentially the same as for our main analyses, with some minor variation in width of confidence intervals. Therefore, the results are only provided in the appendix of meta-analyses (Appendix F), and are not discussed in the text. Next, we did not include studies rated as poor quality in any main analyses, but did include them in sensitivity analyses. Finally, for our meta-analyses of RCTs comparing CEA with medical therapy that included perioperative stroke or death outcomes, we conducted sensitivity analyses including angiogram-related stroke or death occurring prior to surgery (both ACAS and VACS required preoperative confirmatory angiograms) to reflect the harms of the screening cascade if confirmatory angiograms are used. Such events were not included in our main analyses. All quantitative analyses were conducted using Stata^®^ version 11.1 (StataCorp LP, College Station, TX).

## Expert Review and Public Comment

A draft report was reviewed by content experts, USPSTF members, and AHRQ Medical Officers, and was revised based on comments.

## USPSTF Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.