# Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) last reviewed the evidence on screening for carotid artery stenosis (CAS) in 2007^1-3^ and has commissioned an update of the evidence review to revisit its recommendation. The main purpose of this report is to systematically evaluate the current evidence on whether screening asymptomatic adults for CAS reduces the risk for fatal or nonfatal ipsilateral stroke and the evidence on harms associated with screening and interventions for CAS. Despite a D recommendation from the USPSTF in 2007,^3^ many surgeries or interventions for asymptomatic CAS continue to be performed in the United States, and free screenings or those paid for out-of-pocket are offered in public locations across the country.4

The scope and methods of this report differ from earlier USPSTF reviews on this topic by 1) using systematic methods for all key questions (KQs) (the previous review reported using nonsystematic methods for three of its four questions),2 2) addressing new KQs about the availability of valid, reliable risk stratification tools to distinguish a person's likelihood for asymptomatic CAS and to distinguish risk for ipsilateral stroke caused by CAS or for harms from surgery or intervention in persons with asymptomatic CAS (recommendations of some groups state that screening might be considered for persons with multiple risk factors), 3) adding carotid angioplasty and stenting (CAAS) to the included interventions, 4) adding a question about the incremental benefit of medical therapy for asymptomatic CAS, and 5) conducting quantitative synthesis for many outcomes.

## Condition Definition

Carotid artery stenosis refers to atherosclerotic narrowing of the extracranial carotid arteries. It typically refers to the internal carotid arteries or the common and internal carotid arteries. A “clinically important” degree of stenosis is defined as the percentage of stenosis that corresponds to a substantially increased risk for stroke. However, because stroke risk depends on more than just the degree of stenosis, it is difficult to set a lower limit on the range that defines potential clinical importance. The previous USPSTF recommendation considered clinically important CAS as stenosis ranging from 60 percent to 99 percent, but noted that minimum values of 50 percent and 70 percent have been used in some studies. Asymptomatic patients have no significant neurologic symptoms referable to the carotid artery and have not experienced a cerebrovascular event (i.e., a stroke or transient ischemic attack).

## Prevalence and Burden

Stroke is a leading cause of death and disability in the United States. When considered separately from other cardiovascular diseases, stroke ranks as the fourth leading cause of death.5 An estimated 7 million Americans age 20 years and older have had a stroke, and—of the approximately 800,000 strokes that occur in the United States per year—roughly 75 percent are first attacks.6 Overall age-adjusted prevalence of stroke in 2010 was 2.6 percent.7 Ischemic stroke accounts for nearly 90 percent of all strokes in the United States. Carotid artery stenosis is a risk factor for ischemic stroke. Because CAS progresses silently, a stroke can be the first indication of clinically significant stenosis. About 15 percent of ischemic strokes are caused by large artery atherothrombotic disease, which includes CAS.8 Most ischemic strokes are not caused by CAS.

Stroke is among the leading causes of long-term disability in the United States.9 Consequences of ischemic stroke include hemiparesis, aphasia, depression, and an array of limitations on activities of daily living.10 The total cost of stroke in 2008 was $34.3 billion, and the cost of stroke from 2005 to 2050 is projected to exceed $2 trillion.11

The previous USPSTF review estimated the prevalence of 60 percent to 99 percent CAS to be about 1 percent in the general population of asymptomatic persons age 65 years and older. A recent systematic review and meta-analysis of cross-sectional and cohort studies estimated the pooled prevalence of asymptomatic CAS at 50 percent or greater to be 4.2 percent (95% CI, 3.1 to 5.7) and of asymptomatic CAS at 70 percent or greater to be 1.7 percent (95% CI, 0.7 to 3.9).12 Both age and sex influenced the prevalence estimates. For adults younger than age 70 years, the pooled prevalence estimates for CAS at 50 percent or greater were 2.2 percent for women and 4.8 percent for men; for persons age 70 years or older, estimates were 6.9 percent and 12.5 percent, respectively.12 Rates reported in the meta-analysis included complete occlusion (i.e., 100% CAS), and the included studies were quite heterogeneous with respect to demographics, methods of ascertaining stenosis, and quality. Very few studies sampled U.S. general populations, and just four studies, all from outside the United States, contributed data for the analysis of CAS at 70 percent or greater.

The best available data from large U.S.-based studies of the general population (Cardiovascular Health Study) were published in the 1990s and enrolled adults ages 65 and older.14 Data published in 1992 showed prevalence of 75 to 99 percent CAS was 1.07 percent (31/2,906) for women and 1.22 percent (27/2,210) for men.13 Rates for 75 to 100 percent CAS were 1.14 percent and 2.26 percent, respectively. Data published in 1998 suggest an overall prevalence of 70 to 99 percent CAS to be 0.5 percent, based on prevalence of peak systolic velocity greater than or equal to 2.5 m/s.14

## Etiology and Natural History

Carotid artery narrowing is most commonly caused by the buildup of fat, cholesterol, calcium, and other fibrous substances (commonly known as “plaque”) in the arteries over time. Carotid artery stenosis can restrict blood flow to the brain in several ways. This can occur as a result of artery-to-artery embolism of atherosclerotic plaque fragments or thrombotic occlusion of the internal carotid artery. Common contributors to CAS include hypertension, diabetes, smoking, and high cholesterol (particularly a high level of low-density lipoproteins [LDL]).

Several studies have attempted to estimate the rate of progression of asymptomatic CAS and to predict neurologic events resulting from CAS.14-19 Many studies have small samples and are unlikely to be representative of the general asymptomatic population. The potential development of collaterals complicates determining a direct relationship between CAS and resulting stroke; persons with complete occlusion may or may not have a stroke.

The best available data from large U.S.-based studies of the general population (Cardiovascular Health Study) showed a 5 percent 5-year risk for fatal or nonfatal ipsilateral stroke for CAS at 70 percent or greater (n=5,441).14 Smaller studies from single centers in New York (n=425, all asymptomatic) and Illinois (n=142/272 asymptomatic) followed patients with 50 to 79 percent CAS and reported new ipsilateral strokes in 3.8 percent over a mean followup of approximately 3.2 years19 or mean annual stroke rates of 2 percent over a mean followup of approximately 3.7 years.17 Little data on followup beyond 5 years exist; one Canadian cohort study using the subgroup that completed at least 5 years of followup (106 persons from an initial cohort of 500) reported 10- and 15-year rates of 9.3 percent and 16.6 percent, respectively, for patients with 50 to 99 percent CAS.20 Thus, the available data indicate that the vast majority of patients with asymptomatic CAS will not have a stroke caused by their CAS within 5 or 10 years.

In general, risk factors for ischemic stroke are thought to include age greater than 65 years, male sex, hypertension, heart disease, smoking or tobacco use, high blood cholesterol and other lipids, physical inactivity, and diabetes mellitus.21 The previous review for the USPSTF indicated that there are no validated risk stratification tools to discriminate persons with asymptomatic CAS who are at high risk for stroke compared with persons at low risk, although a specific, systematic search for these tools was not conducted.1

## Rationale for Screening and Screening Strategies

Stroke remains a leading cause of death and disability in the United States. In theory, screening might be able to identify asymptomatic CAS for possible treatment before it causes health problems. The most common screening test for CAS is carotid duplex ultrasonography, with or without confirmatory testing using digital subtraction angiography (the gold standard). Because confirmatory testing using digital subtraction angiography can have complications such as stroke, it is rarely used in routine clinical practice. Other potential screening or confirmatory tests include computed tomography angiography (CTA) and magnetic resonance angiography (MRA).

## Treatment Approaches

Potential therapeutic options for asymptomatic CAS include carotid endarterectomy (CEA) and medical therapy, CAAS and medical therapy, or medical therapy alone. In CEA, a surgeon clamps the internal, common, and external carotid arteries, opens the lumen of the internal carotid artery, and removes the plaque. Then, the artery and overlying layers are closed. Many surgeons use a shunt to ensure blood supply to the brain during the procedure. The procedure may be performed under general or local anesthesia.

In CAAS, an interventionist typically accesses the vasculature by inserting a catheter into the femoral artery, up to the aortic arch, and then up the carotid artery. Then, the catheter dilates a balloon to open the artery and inserts a stent to hold it open.

Current standard medical therapy to reduce stroke risk has evolved, and it now includes: use of 3-hydroxy-3-methylglutaryl-coenzyme (HMG-CoA) reductase inhibitors (i.e., statins); control of blood pressure with antihypertensives (including newer classes of medications, such as ACE inhibitors); glycemic control for persons with diabetes; and use of antiplatelet drugs for vascular diseases and risk reduction. Statin therapy, in particular, is thought to have beneficial effects on carotid plaque morphology and the inflammatory response.22 Standard medical practice has evolved as the evidence on screening for CAS has developed. In general, medical therapy in 2014 is more aggressive in reaching lower blood pressure and LDL targets than it was 10 years ago. Thus, the risk for stroke has decreased with improvements in medical therapy. Lifestyle modifications (smoking cessation, increased physical activity, improved diet) may also help prevent carotid stenosis–related stroke.21

Decisions between various treatment approaches may involve tradeoffs between benefits and risks. For example, surgery or intervention may introduce significant short-term risks of stroke, death, or myocardial infarction (MI) (as harms of surgery or intervention) in exchange for long-term reduction in risks of stroke or death.

## Current Clinical Practice in the United States

Large studies involving data from Medicare claims show significant geographic variation in the rates of CEA and, to a lesser extent, carotid stenting; however, these studies may be limited by their ability to collect detailed information on symptom status. One cohort study of Medicare beneficiaries reported rates of 2.8 CEAs per 1,000 beneficiaries and 0.3 CAASs per 1,000 beneficiaries.23 Substantial geographic variation existed, with a nearly nine-fold difference between the highest rate and lowest rates of CEAs across hospital referral regions.23 This same study also found considerable variation in the type of diagnostic imaging performed before carotid revascularization.

Accurate information on current rates of CEA and carotid stenting for asymptomatic patients in the general population is difficult to obtain because detailed data on symptom status may not reside in large registries (e.g., Medicare claims data). One study of Medicare beneficiaries in New York state linked Medicare claims with medical records (including detailed information on symptom status) and found that about three-quarters (72.3%) of patients who underwent CEA in 2007 were asymptomatic.24 A smaller 2012 study conducted in four urban hospitals found that 63 percent of CEAs performed within a 2-year period were for asymptomatic patients.25 Evidence also reveals variation in the use of procedures by physician specialty. A recent analysis of carotid stenting in Medicare beneficiaries found that cardiologists perform half of the procedures and significant differences were noted in the characteristics of patients treated by cardiologists compared with other specialists.26 Population-based utilization rates for carotid stenting were significantly higher in hospital referral regions where cardiologists performed most procedures compared with regions where other specialists primarily performed the procedures. Although detailed symptom status was not available, patients treated by cardiologists had fewer neurologic conditions, including less evidence of recent acute stroke or transient ischemic attack, in the 180 days prior to stenting. More than 50 percent of patients treated by cardiologists also underwent cardiac catheterization prior to carotid stenting and had carotid and cerebral angiography performed simultaneously, suggesting the possibility that routine case findings of severe CAS by cardiologists during diagnostic angiography influenced patient selection.26

## Previous USPSTF Recommendation

In 2007, the USPSTF recommended that providers should not screen for asymptomatic CAS in the general adult population (D recommendation).3 Recommendations from other groups similarly discourage screening for the general population. However, several guidelines suggest that screening for asymptomatic CAS may be appropriate for patients thought to be at high risk (Appendix A).