# Quality Assessment of Included Studies

Appendix D Table 1 Quality Ratings for Studies of Risk Stratification Tools (KQ 2)

Appendix D Table 2 Quality Ratings for Systematic Reviews of Accuracy of Duplex Ultrasonography (KQ 3)

Appendix D Table 3 Quality Ratings for Primary Studies of Accuracy of Duplex Ultrasonography (KQ 3)

Appendix D Table 4 Quality Ratings for Systematic Reviews and Meta-Analyses for Benefit of Treatment (KQ 5)

Appendix D Table 5 Quality Ratings for Randomized, Controlled Trials for Benefit of Treatment (KQ 5)

Appendix D Table 6 Quality Ratings for Randomized, Controlled Trials for Harms of Treatment (KQ 8)

Appendix D Table 7 Quality Ratings for Other Studies for Harms of Treatment (KQ 8)

## Appendix D. References

1 Suri MF, Ezzeddine MA, Lakshminarayan K, et al. Validation of two different grading schemes to identify patients with asymptomatic carotid artery stenosis in general population. J Neuroimaging. Apr. 2008;18(2):142-7. [pmid: 18380694].
2 Jacobowitz GR, Rockman CB, Gagne PJ, et al. A model for predicting occult carotid artery stenosis: screening is justified in a selected population. J Vasc Surg. Oct. 2003;38(4):705-9. [pmid: 14560217].
3 Qureshi AI, Janardhan V, Bennett SE, et al. Who should be screened for asymptomatic carotid artery stenosis? Experience from the Western New York Stroke Screening Program. J Neuroimaging. Apr. 2001;11(2):105-11. [pmid: 11296578].
4 Jahromi AS, Cina CS, Liu Y, et al. Sensitivity and specificity of color duplex ultrasound measurement in the estimation of internal carotid artery stenosis: a systematic review and meta-analysis. J Vasc Surg. Jun. 2005;41(6):962-72. [pmid: 15944595].
5 Nederkoorn PJ, Graaf Y, Hunink M. Duplex ultrasound and magnetic resonance angiography compared with digital subtraction angiography in carotid artery stenosis: a systematic review. (Structured abstract). Stroke. 2003;34(5):1324-31. [pmid: 12690221].
6 Blakeley DD, Oddone EZ, Hasselblad V, et al. Noninvasive carotid artery testing. A meta-analytic review. Ann Intern Med. 1995;122(5):360-7. [pmid: 7847648].
7 Jogestrand T, Lindqvist M, Nowak J. Diagnostic performance of duplex ultrasonography in the detection of high grade internal carotid artery stenosis. Eur J Vasc Endovasc Surg. Jun. 2002;23(6):510-8. [pmid: 12093067].
8 Nowak J, Jogestrand T. Duplex ultrasonography is an efficient diagnostic tool for the detection of moderate to severe internal carotid artery stenosis. Clin Physiol Funct Imaging. May. 2007;27(3):144-7. [pmid: 17445064].
9 Sabeti S, Schillinger M, Mlekusch W, et al. Quantification of internal carotid artery stenosis with duplex US: comparative analysis of different flow velocity criteria. Radiology. Aug. 2004;232(2):431-9. [pmid: 15286315].
10 Hwang CS, Liao KM, Lee JH, et al. Measurement of carotid stenosis: comparisons between duplex and different angiographic grading methods. J Neuroimaging. Apr. 2003;13(2):133-9. [pmid: 12722495].
11 Benavente O, Moher D, Pham B. Carotid endarterectomy for asymptomatic carotid stenosis: a meta-analysis. BMJ. Nov. 28. 1998;317(7171):1477-80. [pmid: 9831572].
12 Chambers Brian R, Donnan G. Carotid endarterectomy for asymptomatic carotid stenosis. Cochrane Database Syst Rev. 2005;(4).
13 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for Asymptomatic Carotid Artery Stenosis. Evidence Synthesis Number 50. AHRQ Publication No. 08-05102-EF-1. Agency for Healthcare Research and Quality. December. 2007. Rockville, MD.
14 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for carotid artery stenosis: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 18. 2007;147(12):860-70. [pmid: 18087057].
15 Raman G, Kitsios GD, Moorthy D, et al. Management of Asymptomatic Carotid Artery Stenosis. Technology Assessment Report. Project ID: CRDT0510. Prepared for the Agency for Healthcare Research and Quality by the Tufts Evidence-based Practice Center. Rockville, MD. August. 27. 2012.
16 Raman G, Moorthy D, Hadar N, et al. Management Strategies for Asymptomatic Carotid Stenosis: A Systematic Review and Meta-analysis. Ann Intern Med. May. 7. 2013;158(9):676-85. [pmid: 23648949].
17 Guay J, Ochroch EA. Carotid endarterectomy plus medical therapy or medical therapy alone for carotid artery stenosis in symptomatic or asymptomatic patients: a meta-analysis. (Structured abstract). Cardiothorac Vasc Anesth. 2012;26(5):835-44.
18 Halliday A, Mansfield A, Marro J, et al. Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. May. 8. 2004;363(9420):1491-502. [pmid: 15135594].
19 Halliday A, Harrison M, Hayter E, et al. 10-year stroke prevention after successful carotid endarterectomy for asymptomatic stenosis (ACST-1): a multicentre randomised trial. Lancet. Sep. 25. 2010;376(9746):1074-84. [pmid: 20870099].
20 den Hartog AG, Halliday AW, Hayter E, et al. Risk of stroke from new carotid artery occlusion in the Asymptomatic Carotid Surgery Trial-1. Stroke. Jun. 2013;44(6):1652-9. [pmid: 23632980].
21 Halliday AW, Thomas D, Mansfield A. The Asymptomatic Carotid Surgery Trial (ACST). Rationale and design. Steering Committee. Eur J Vasc Surg. 1994;8(6):703-10. [pmid: 7828747].
22 Halliday AW, Thomas DJ, Mansfield AO. The asymptomatic carotid surgery trial (ACST). International angiology : a journal of the International Union of Angiology. 1995;14(1):18-20. [pmid: 7658099].
23 Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. JAMA. May. 10. 1995;273(18):1421-8. [pmid: 7723155].
24 Baker WH, Howard VJ, Howard G, et al. Effect of contralateral occlusion on long-term efficacy of endarterectomy in the asymptomatic carotid atherosclerosis study (ACAS). ACAS Investigators. Stroke. Oct. 2000;31(10):2330-4. [pmid: 11022059].
25 Young B, Moore WS, Robertson JT, et al. An analysis of perioperative surgical mortality and morbidity in the asymptomatic carotid atherosclerosis study. Stroke. 1996;27(12):2216-24. [pmid: 8969784].
26 Towne JB, Weiss DG, Hobson RW. First phase report of cooperative Veterans Administration asymptomatic carotid stenosis study--operative morbidity and mortality. J Vasc Surg. 1990;11(2):252-8. discussion 8-9. [pmid: 2405197].
27 Hobson RW 2nd, Weiss DG, Fields WS, et al. Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. N Engl J Med. Jan. 28. 1993;328(4):221-7. [pmid: 8418401].
28 Role of carotid endarterectomy in asymptomatic carotid stenosis. A Veterans Administration Cooperative Study. Stroke; a journal of cerebral circulation. 1986;17(3):534-9.
29 Kresowik Tea. Multistate improvement in process and outcomes of carotid endarterectomy. J Vasc Surg. 2004;39(2).
30 Kresowik TF, Bratzler D, Karp HR, et al. Multistate utilization, processes, and outcomes of carotid endarterectomy. J Vasc Surg. Feb. 2001;33(2):227-34. discussion 34-5. [pmid: 11174772].
31 Bratzler DW, Oehlert WH, Murray CK, et al. Carotid endarterectomy in Oklahoma Medicare beneficiaries: patient characteristics and outcomes. J Okla State Med Assoc. Dec. 1996;89(12):423-9. [pmid: 8997882].
32 Cebul RD, Snow RJ, Pine R, et al. Indications, outcomes, and provider volumes for carotid endarterectomy. JAMA. Apr. 22-29. 1998;279(16):1282-7. [pmid: 9565009].
33 Halm EA, Tuhrim S, Wang JJ, et al. Has evidence changed practice?: appropriateness of carotid endarterectomy after the clinical trials. Neurology. Jan. 16. 2007;68(3):187-94. [pmid: 17224571].
34 Halm EA, Tuhrim S, Wang JJ, et al. Risk factors for perioperative death and stroke after carotid endarterectomy: results of the new york carotid artery surgery study. Stroke. Jan. 2009;40(1):221-9. [pmid: 18948605].
35 Halm EA, Chassin MR, Tuhrim S, et al. Revisiting the appropriateness of carotid endarterectomy. Stroke. Jun. 2003;34(6):1464-71. [pmid: 12738896].
36 Rockman CB, Halm EA, Wang JJ, et al. Primary closure of the carotid artery is associated with poorer outcomes during carotid endarterectomy. J Vasc Surg. Nov. 2005;42(5):870-7. [pmid: 16275440].
37 Halm EA, Hannan EL, Rojas M, et al. Clinical and operative predictors of outcomes of carotid endarterectomy. J Vasc Surg. Sep. 2005;42(3):420-8. [pmid: 16171582].
38 Press MJ, Chassin MR, Wang J, et al. Predicting medical and surgical complications of carotid endarterectomy: comparing the risk indexes. Arch Intern Med. Apr. 24. 2006;166(8):914-20. [pmid: 16636219].
39 Karp HR, Flanders WD, Shipp CC, et al. Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome. Stroke. Jan. 1998;29(1):46-52. [pmid: 9445327].
40 Kresowik TF, Hemann RA, Grund SL, et al. Improving the outcomes of carotid endarterectomy: results of a statewide quality improvement project. J Vasc Surg. May. 2000;31(5):918-26. [pmid: 10805882].
41 Giacovelli JK, Egorova N, Dayal R, et al. Outcomes of carotid stenting compared with endarterectomy are equivalent in asymptomatic patients and inferior in symptomatic patients. J Vasc Surg. Oct. 2010;52(4):906-13. 13 e1. 4. [pmid: 20620010].
42 Vouyouka AG, Egorova NN, Sosunov EA, et al. Analysis of Florida and New York state hospital discharges suggests that carotid stenting in symptomatic women is associated with significant increase in mortality and perioperative morbidity compared with carotid endarterectomy. J Vasc Surg. Aug. 2012;56(2):334-42. [pmid: 22583852].
43 McPhee JT, Hill JS, Ciocca RG, et al. Carotid endarterectomy was performed with lower stroke and death rates than carotid artery stenting in the United States in 2003 and 2004. J Vasc Surg. Dec. 2007;46(6):1112-8. [pmid: 18154987].
44 McPhee JT, Schanzer A, Messina LM, et al. Carotid artery stenting has increased rates of postprocedure stroke, death, and resource utilization than does carotid endarterectomy in the United States, 2005. J Vasc Surg. Dec. 2008;48(6):1442-50. 50 e1. [pmid: 18829236].
45 Timaran CH, Veith FJ, Rosero EB, et al. Intracranial hemorrhage after carotid endarterectomy and carotid stenting in the United States in 2005. J Vasc Surg. Mar. 2009;49(3):623-8. discussion 8-9. [pmid: 19268766].
46 Giles KA, Hamdan AD, Pomposelli FB, et al. Stroke and death after carotid endarterectomy and carotid artery stenting with and without high risk criteria. J Vasc Surg. Dec. 2010;52(6):1497-504. [pmid: 20864299].
47 Young KC, Jahromi BS. Does current practice in the United States of carotid artery stent placement benefit asymptomatic octogenarians?. AJNR Am J Neuroradiol. Jan. 2011;32(1):170-3. [pmid: 20864521].
48 Horner RD, Oddone EZ, Stechuchak KM, et al. Racial variations in postoperative outcomes of carotid endarterectomy: evidence from the Veterans Affairs National Surgical Quality Improvement Program. Med Care. Jan. 2002;40(1 Suppl):I35-43. [pmid: 11789630].
49 Samsa G, Oddone EZ, Horner R, et al. To what extent should quality of care decisions be based on health outcomes data? Application to carotid endarterectomy. Stroke. Dec. 2002;33(12):2944-9. [pmid: 12468795].
50 Woo K, Garg J, Hye RJ, et al. Contemporary results of carotid endarterectomy for asymptomatic carotid stenosis. Stroke. May. 2010;41(5):975-9. [pmid: 20339122].
51 Garg J, Frankel DA, Dilley RB. Carotid endarterectomy in academic versus community hospitals: the national surgical quality improvement program data. Ann Vasc Surg. May. 2011;25(4):433-41. [pmid: 21435832].
52 Wallaert JB, De Martino RR, Finlayson SR, et al. Carotid endarterectomy in asymptomatic patients with limited life expectancy. Stroke. Jul. 2012;43(7):1781-7. [pmid: 22550053].
53 Theiss W, Hermanek P, Mathias K, et al. Predictors of death and stroke after carotid angioplasty and stenting: a subgroup analysis of the Pro-CAS data. Stroke. Aug. 2008;39(8):2325-30. [pmid: 18583556].
54 Palombo D, Lucertini G, Mambrini S, et al. Carotid endarterectomy: results of the Italian Vascular Registry. J Cardiovasc Surg (Torino). Apr. 2009;50(2):183-7. [pmid: 19282808].
55 Micari A, Stabile E, Cremonesi A, et al. Carotid artery stenting in octogenarians using a proximal endovascular occlusion cerebral protection device: a multicenter registry. Catheter Cardiovasc Interv. Jul. 1. 2010;76(1):9-15. [pmid: 20578188].
56 Menyhei G, Bjorck M, Beiles B, et al. Outcome following carotid endarterectomy: lessons learned from a large international vascular registry. Eur J Vasc Endovasc Surg. Jun. 2011;41(6):735-40. [pmid: 21450496].
57 Lindstrom D, Jonsson M, Formgren J, et al. Outcome after 7 years of carotid artery stenting and endarterectomy in Sweden - single centre and national results. Eur J Vasc Endovasc Surg. May. 2012;43(5):499-503. [pmid: 22342694].
58 Sidawy AN, Zwolak RM, White RA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. J Vasc Surg. Jan. 2009;49(1):71-9. [pmid: 19028045].
59 Jim J, Rubin BG, Ricotta JJ 2nd, et al. Society for Vascular Surgery (SVS) Vascular Registry evaluation of comparative effectiveness of carotid revascularization procedures stratified by Medicare age. J Vasc Surg. May. 2012;55(5):1313-20. discussion 21. [pmid: 22459755].
60 Carotid surgery versus medical therapy in asymptomatic carotid stenosis. The CASANOVA Study Group. Stroke. Oct. 1991;22(10):1229-35. [pmid: 1926232].
61 Wiebers DO, Whisnant JP, Meissner I, et al. Results of a randomized controlled trial of carotid endarterectomy for asymptomatic carotid stenosis. Mayo Clin Proc. 1992;67(6):513-8. [pmid: 1434877].
62 Fairman R, Gray WA, Scicli AP, et al. The CAPTURE registry: analysis of strokes resulting from carotid artery stenting in the post approval setting: timing, location, severity, and type. Ann Surg. Oct. 2007;246(4):551-6. discussion 6-8. [pmid: 17893491].
63 Gray WA, Chaturvedi S, Verta P. Thirty-day outcomes for carotid artery stenting in 6320 patients from 2 prospective, multicenter, high-surgical-risk registries. Circ Cardiovasc Interv. Jun. 2009;2(3):159-66. [pmid: 20031712].
64 Chaturvedi S, Matsumura JS, Gray W, et al. Carotid artery stenting in octogenarians: periprocedural stroke risk predictor analysis from the multicenter Carotid ACCULINK/ACCUNET Post Approval Trial to Uncover Rare Events (CAPTURE 2) clinical trial. Stroke. Apr. 2010;41(4):757-64. [pmid: 20185789].
65 Matsumura JS, Gray W, Chaturvedi S, et al. CAPTURE 2 risk-adjusted stroke outcome benchmarks for carotid artery stenting with distal embolic protection. J Vasc Surg. Sep. 2010;52(3):576-83. 83 e1. 83 e2. [pmid: 20576398].
66 CaRESS Steering Committee. Carotid revascularization using endarterectomy or stenting systems (CARESS): Phase I clinical trial. J Endovasc Ther. Dec. 2003;10(6):1021-30. [pmid: 14723574].
67 McKinlay SM. Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) phase I clinical trial: 1-Year results. J Vasc Surg. 2005;42(2):213-9. [pmid: 16102616].
68 Zarins CK, White RA, Diethrich EB, et al. Carotid revascularization using endarterectomy or stenting systems (CaRESS): 4-year outcomes. J Endovasc Ther. Aug. 2009;16(4):397-409. [pmid: 19702339].
69 Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. N Engl J Med. Oct. 7. 2004;351(15):1493-501. [pmid: 15470212].
70 Brott TG, Hobson RW 2nd, Howard G, et al. Stenting versus endarterectomy for treatment of carotid-artery stenosis. N Engl J Med. Jul. 1. 2010;363(1):11-23. [pmid: 20505173].
71 Silver FL, Mackey A, Clark WM, et al. Safety of stenting and endarterectomy by symptomatic status in the Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST). Stroke. Mar. 2011;42(3):675-80. [pmid: 21307169].
72 Hopkins LN, Roubin GS, Chakhtoura EY, et al. The Carotid Revascularization Endarterectomy versus Stenting Trial: credentialing of interventionalists and final results of lead-in phase. Journal of stroke and cerebrovascular diseases : the official journal of National Stroke Association. 2010;19(2):153-62. [pmid: 20189092].
73 Mercado N, Cohen DJ, Spertus JA, et al. Carotid artery stenting of a contralateral occlusion and in-hospital outcomes: results from the CARE (Carotid Artery Revascularization and Endarterectomy) registry. JACC Cardiovasc Interv. Jan. 2013;6(1):59-64. [pmid: 23347862].
74 Yuo TH, Degenholtz HS, Chaer RA, et al. Effect of hospital-level variation in the use of carotid artery stenting versus carotid endarterectomy on perioperative stroke and death in asymptomatic patients. J Vasc Surg. Mar. 2013;57(3):627-34. [pmid: 23312937].
75 Schermerhorn ML, Fokkema M, Goodney P, et al. The impact of Centers for Medicare and Medicaid Services high-risk criteria on outcome after carotid endarterectomy and carotid artery stenting in the SVS Vascular Registry. J Vasc Surg. May. 2013;57(5):1318-24. [pmid: 23406712].
76 Fokkema M, Bensley RP, Lo RC, et al. In-hospital versus postdischarge adverse events following carotid endarterectomy. J Vasc Surg. Jun. 2013;57(6):1568-75. 75 e1. 3. [pmid: 23388394].
77 Rajamani K, Kennedy KF, Ruggiero NJ, et al. Outcomes of carotid endarterctomy in the elderly: A report from the care registry(registered trademark). Stroke. 2012;43(2).