# Excluded Studies

## Not Original Research

1 Power Doppler detects stroke risk in patients without stenosis symptoms. Geriatrics. 2000;55(8):15-22.
2 Barnett HJ, Meldrum HE. The outlook for patients with carotid stenosis. Cerebrovasc Dis. 2000;10(Suppl 4):30-5. [pmid: 11070398].
3 Hankey GJ. Carotid endarterectomy for asymptomatic carotid stenosis. Ann Intern Med. 1993;118(Suppl 3):72.
4 Khan N, Murphy TP, Haas RA, et al. Stroke prevention. Med Health R I. 2005;88(2):44-7. [pmid: 15816244].
5 Meissner I. Symptomatic carotid stenosis: precarotid endarterectomy evaluation. J Neurosurg Anesthesiol. 1996;8(4):308-9. [pmid: 8884629].
6 Newell DW, Grady MS, Nicholls SC. Cervical carotid to petrous carotid bypass for lesions of the upper cervical carotid artery. Ann Vasc Surg. 1996;10(1):76-87. [pmid: 8688302].
7 Sacco RL. Extracranial carotid stenosis. N Engl J Med. 2001;345(15):1113-8. [pmid: 11596592].
8 Towne JB, Hobson RW. Current status of operative treatment for asymptomatic carotid stenosis. Can J Surg. 1994;37(2):128-34. [pmid: 8156465].

## Ineligible Population

1 AbuRahma AF, Bates MC, Eads K, et al. Safety and efficacy of carotid angioplasty/stenting in 100 consecutive high surgical risk patients: immediate and long-term follow-up. Vasc Endovascular Surg. 2008;42(5):433-9. [pmid: 18583300].
2 Ackerstaff RG, Moons KG, van de Vlasakker CJ, et al. Association of intraoperative transcranial doppler monitoring variables with stroke from carotid endarterectomy. Stroke. 2000;31(8):1817-23. [pmid: 10926940].
3 Ahari A, Bergqvist D, Troeng T, et al. Diabetes mellitus as a risk factor for early outcome after carotid endarterectomy--a population-based study. Eur J Vasc Endovasc Surg. 1999;18(2):122-6. [pmid: 10428751].
4 Alexandrova NA, Gibson WC, Norris JW, et al. Carotid artery stenosis in peripheral vascular disease. J Vasc Surg. 1996;23(4):645-9. [pmid: 8627901].
5 Amato B, Markabaoui AK, Piscitelli V, et al. Carotid endarterectomy under local anesthesia in elderly: is it worthwhile?. Acta Biomed. 2005;76(Suppl 1):64-8. [pmid: 16450515].
6 Aoki J, Kimura K, Iguchi Y, et al. A combined TCD and MRA screening for significant siphon portion of internal carotid artery (S-ICA) stenosis. J Neuroimaging. 2012;22(2):172-6. [pmid: 21223433].
7 Beilby JP, Hunt CC, Palmer LJ, et al. Apolipoprotein E gene polymorphisms are associated with carotid plaque formation but not with intima-media wall thickening: results from the Perth Carotid Ultrasound Disease Assessment Study (CUDAS). Stroke. 2003;34(4):869-74. [pmid: 12637699].
8 Biasi GM, Froio A, Diethrich EB, et al. Carotid plaque echolucency increases the risk of stroke in carotid stenting: the Imaging in Carotid Angioplasty and Risk of Stroke (ICAROS) study. Circulation. 2004;110(6):756-62. [pmid: 15277320].
9 Bonati Leo H, Lyrer P, Ederle J, et al. Percutaneous transluminal balloon angioplasty and stenting for carotid artery stenosis. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2012.
10 Bond R, Narayan SK, Rothwell PM, et al. Clinical and radiographic risk factors for operative stroke and death in the European carotid surgery trial. Eur J Vasc Endovasc Surg. 2002;23(2):108-16. [pmid: 11863327].
11 Bond R, Rerkasem K, Cuffe R, et al. A systematic review of the associations between age and sex and the operative risks of carotid endarterectomy. Cerebrovasc Dis. 2005;20(2):69-77. [pmid: 15976498].
12 Borisch I, Horn M, Butz B, et al. Preoperative evaluation of carotid artery stenosis: comparison of contrast-enhanced MR angiography and duplex sonography with digital subtraction angiography. Am J Neuroradiol. 2003;24(6):1117-22. [pmid: 12812936].
13 Bosiers M, De Donato G, Deloose K, et al. Are there predictive risk factors for complications after carotid artery stenting?. J Cardiovasc Surg (Torino). 2007;48(2):125-30. [pmid: 17410060].
14 Bots ML, van Swieten JC, Breteler MM, et al. Cerebral white matter lesions and atherosclerosis in the Rotterdam Study. Lancet. 1993;341(8855):1232-7. [pmid: 8098390].
15 Brown HA, Sullivan MC, Gusberg RG, Dardik A, Sosa JA, Indes JE. Race as a predictor of morbidity, mortality, and neurologic events after carotid endarterectomy. J Vasc Surg. 2013;57(5):1325-1330. [pmid: 23375438].
16 Bush RL, Kougias P, Guerrero MA, et al. A comparison of carotid artery stenting with neuroprotection versus carotid endarterectomy under local anesthesia. Am J Surg. 2005;190(5):696-700. [pmid: 16226942].
17 Cao P, De Rango P, Zannetti S. Eversion vs conventional carotid endarterectomy: a systematic review. Eur J Vasc Endovasc Surg. 2002;23(3):195-201. [pmid: 11914004].
18 Carmody BJ, Arora S, Avena R, et al. Accelerated carotid artery disease after high-dose head and neck radiotherapy: is there a role for routine carotid duplex surveillance?. J Vasc Surg. 1999;30(6):1045-51. [pmid: 10587388].
19 Chang JB, Stein TA. Late stroke in patients after carotid endarterectomy. J Surg Res. 1997;73(2):155-9. [pmid: 9441810].
20 Chang JB, Stein TA. Ten-year outcome after saphenous vein patch angioplasty in males and females after carotid endarterectomy. Vasc Endovascular Surg. 2002;36(1):21-7. [pmid: 12704521].
21 Collins P, McKay I, Rajagoplan S, et al. Is carotid duplex scanning sufficient as the sole investigation prior to carotid endarterectomy?. Br J Radiol. 2005;78(935):1034-7. [pmid: 16249605].
22 Dean N, Lari H, Saqqur M, et al. Reliability of carotid doppler performed in a dedicated stroke prevention clinic. Can J Neurol Sci. 2005;32(3):327-31. [pmid: 16225174].
23 Debing E, Van den Brande P. Does the type, number or combinations of traditional cardiovascular risk factors affect early outcome after carotid endarterectomy?. Eur J Vasc Endovasc Surg. 2006;31(6):622-6. [pmid: 16466942].
24 Droste DW, Jurgens R, Weber S, et al. Benefit of echocontrast-enhanced transcranial color-coded duplex ultrasound in the assessment of intracranial collateral pathways. Stroke. 2000;31(4):920-3. [pmid: 10753999].
25 Duncan JM, Reul GJ, Ott DA, et al. Outcomes and risk factors in 1,609 carotid endarterectomies. Tex Heart Inst J. 2008;35(2):104-10. [pmid: 18612484].
26 Endo S, Kuwayama N, Hirashima Y. Japan Carotid Atherosclerosis Study: JCAS. Neurol Med Chir (Tokyo). 2004;44(4):215-7. [pmid: 15185764].
27 Engelhardt M, Bruijnen H, Schnur C, et al. Duplex scanning criteria for selection of patients for internal carotid artery endarterectomy. Vasa. 2005;34(1):36-40. [pmid: 15786936].
28 Engelter S, Lyrer P. Antiplatelet therapy for preventing stroke and other vascular events after carotid endarterectomy. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2003.
29 Fabris F, Zanocchi M, Bo M, et al. Carotid plaque, aging, and risk factors. A study of 457 subjects. Stroke. 1994;25(6):1133-40. [pmid: 8202970].
30 Flis V, Tetickovic E, Breznik S, et al. The measurement of stenosis of the internal carotid artery: comparison of doppler ultrasound, digital subtraction angiography and the 3D CT volume rendering technique. Wien Klin Wochenschr. 2004;116(Suppl 2):51-5. [pmid: 15506311].
31 Florio F, Nardella M, Balzano S, et al. Preoperative assessment of stenosis of the epiaortic vessels: can colour-Doppler ultrasound really supplant angiography?. Radiol Med. 2003;105(4):362-9. [pmid: 12835630].
32 Fujimoto S, Toyoda K, Kishikawa K, et al. Accuracy of conventional plus transoral carotid ultrasonography in distinguishing pseudo-occlusion from total occlusion of the internal carotid artery. Cerebrovasc Dis. 2006;22(2-3):170-6. [pmid: 16710083].
33 Gabrusiewicz A, Staszkiewicz W, Slowinski P, et al. Clinical assessment of the factors influencing neurological deficits during carotid endarterectomy. Chirurgia Polska. 2007;9(2):69-77.
34 Gao MY, Sillesen HH, Lorentzen JE, et al. Eversion carotid endarterectomy generates fewer microemboli than standard carotid endarterectomy. Eur J Vasc Endovasc Surg. 2000;20(2):153-7. [pmid: 10942686].
35 Goodney PP, Likosky DS, Cronenwett JL. Factors associated with stroke or death after carotid endarterectomy in Northern New England. J Vasc Surg. 2008;48(5):1139-45. [pmid: 18586446].
36 Grego F, Lepidi S, Antonello M, et al. Is carotid endarterectomy in octogenarians more dangerous than in younger patients?. J Cardiovasc Surg (Torino). 2005;46(5):477-83. [pmid: 16278638].
37 Griewing B, Brassel F, Von Smekal U, et al. Carotid artery stenting in patients at surgical high risk: clinical and ultrasound findings. Cerebrovasc Dis. 2000;10(1):44-8. [pmid: 10629346].
38 Gupta PK, Pipinos II, Miller WJ, et al. A population-based study of risk factors for stroke after carotid endarterectomy using the ACS NSQIP database. J Surg Res. 2011;167(2):182-91. [pmid: 21109261].
39 Hart JP, Peeters P, Verbist J, et al. Do device characteristics impact outcome in carotid artery stenting?. J Vasc Surg. 2006;44(4):725-30. [pmid: 17011998].
40 Harthun NL, Kongable GL, Baglioni AJ, et al. Examination of sex as an independent risk factor for adverse events after carotid endarterectomy. J Vasc Surg. 2005;41(2):223-30. [pmid: 15768003].
41 Hashimoto H, Tagaya M, Niki H, et al. Computer-assisted analysis of heterogeneity on B-mode imaging predicts instability of asymptomatic carotid plaque. Cerebrovasc Dis. 2009;28(4):357-64. [pmid: 19628937].
42 Hayes PD, Allroggen H, Steel S, et al. Randomized trial of vein versus Dacron patching during carotid endarterectomy: influence of patch type on postoperative embolization. J Vasc Surg. 2001;33(5):994-1000. [pmid: 11331840].
43 Helm EE. Clinical and operative predictors of outcomes of carotid endarterectomy. J Vasc Surg. 2005;42(3).
44 Henry M, Henry I, Polydorou A, et al. Carotid angioplasty and stenting in octogenarians: is it safe?. Catheter Cardiovasc Interv. 2008;72(3):309-17. [pmid: 18729151].
45 Henry MC, Henry I, Benjelloun A. Carotid angioplasty and stenting in octogenarians is as safe as surgery. Heart Surg Forum. 2012;15:S51-S2.
46 Herzig R, Burval S, Krupka B, et al. Comparison of ultrasonography, CT angiography, and digital subtraction angiography in severe carotid stenoses. Eur J Neurol. 2004;11(11):774-81. [pmid: 15525300].
47 Heyer EJ, Wilson DA, Sahlein DH, et al. APOE-ɛ4 predisposes to cognitive dysfunction following uncomplicated carotid endarterectomy. Neurology. 2005;65(11):1759-63. [pmid: 16207841].
48 Hsia DC, Moscoe LM, Krushat WM. Epidemiology of carotid endarterectomy among Medicare beneficiaries: 1985-1996 update. Stroke. 1998;29(2):346-50. [pmid: 9472872].
49 Jackson RS, Black JH 3rd, Lum YW, et al. Class I obesity is paradoxically associated with decreased risk of postoperative stroke after carotid endarterectomy. J Vasc Surg. 2012;55(5):1306-12. [pmid: 22542344].
50 Jung EM, Kubale R, Ritter G, et al. Diagnostics and characterisation of preocclusive stenoses and occlusions of the internal carotid artery with B-flow. Eur Radiol. 2007;17(2):439-47. [pmid: 16703310].
51 Katz SG, Kohl RD. Does the choice of material influence early morbidity in patients undergoing carotid patch angioplasty?. Surgery. 1996;119(3):297-301. [pmid: 8619185].
52 Kerdiles Y, Lucas A, Podeur L, et al. Results of carotid surgery in elderly patients. J Cardiovasc Surg (Torino). 1997;38(4):327-34. [pmid: 9267339].
53 Kimouli M, Miyakis S, Georgakopoulos P, et al. Polymorphisms of fractalkine receptor CX3CR1 gene in patients with symptomatic and asymptomatic carotid artery stenosis. J Atheroscler Thromb. 2009;16(5):604-10. [pmid: 19755791].
54 Koelemay ME. Systematic review of computed tomographic angiography for assessment of carotid artery disease. Stroke. 2004;35(10).
55 Kragsterman B, Logason K, Ahari A, et al. Risk factors for complications after carotid endarterectomy--a population-based study. Eur J Vasc Endovasc Surg. 2004;28(1):98-103. [pmid: 15177238].
56 Kucey DS, Bowyer B, Iron K, et al. Determinants of outcome after carotid endarterectomy. J Vasc Surg. 1998;28(6):1051-8. [pmid: 9845656].
57 Kueh SH, Livingstone V, Thomson IA. Carotid endarterectomy in octogenarians. N Z Med J. 2012;125(1364):77-82. [pmid: 23242400].
58 Kuhan G, Gardiner ED, Abidia AF, et al. Risk modelling study for carotid endarterectomy. Br J Surg. 2001;88(12):1590-4. [pmid: 11736969].
59 Kuntz KM, Polak JF, Whittemore AD, et al. Duplex ultrasound criteria for the identification of carotid stenosis should be laboratory specific. Stroke. 1997;28(3):597-602. [pmid: 9056618].
60 Lawrence PF, Alves JC, Jicha D, et al. Incidence, timing, and causes of cerebral ischemia during carotid endarterectomy with regional anesthesia. J Vasc Surg. 1998;27(2):329-34. [pmid: 9510287].
61 Lennard N, Smith JL, Gaunt ME, et al. A policy of quality control assessment helps to reduce the risk of intraoperative stroke during carotid endarterectomy. Eur J Vasc Endovasc Surg. 1999;17(3):234-40. [pmid: 10092897].
62 Lernfelt B, Forsberg M, Blomstrand C, et al. Cerebral atherosclerosis as predictor of stroke and mortality in representative elderly population. Stroke. 2002;33(1):224-9. [pmid: 11779914].
63 Liapis CD, Kakisis JD, Papavassiliou VG, et al. Risk factors associated with recurrent carotid artery stenosis. Vasc Surg. 1999;33(6):697-704.
64 Lindgren A, Roijer A, Rudling O, et al. Cerebral lesions on magnetic resonance imaging, heart disease, and vascular risk factors in subjects without stroke. A population-based study. Stroke. 1994;25(5):929-34. [pmid: 8165686].
65 Logason K, Karacagil S, Hardemark HG, et al. Carotid artery endarterectomy solely based on duplex scan findings. Vasc Surg. 2002;36(1):9-15.
66 Lopez-Cancio E, Dorado L, Millan M, et al. The Barcelona-Asymptomatic Intracranial Atherosclerosis (AsIA) study: prevalence and risk factors. Atherosclerosis. 2012;221(1):221-5. [pmid: 22245037].
67 Lyrer P, Engelter S. Antithrombotic drugs for carotid artery dissection. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2010.
68 Madycki G, Staszkiewicz W, Gabrusiewicz A. Carotid plaque texture analysis can predict the incidence of silent brain infarcts among patients undergoing carotid endarterectomy. Eur J Vasc Endovasc Surg. 2006;31(4):373-80. [pmid: 16427334].
69 Manheim LM, Sohn MW, Feinglass J, et al. Hospital vascular surgery volume and procedure mortality rates in California, 1982-1994. J Vasc Surg. 1998;28(1):45-56. [pmid: 9685130].
70 Mathiesen EB, Bonaa KH, Joakimsen O. Echolucent plaques are associated with high risk of ischemic cerebrovascular events in carotid stenosis: the Tromso study. Circulation. 2001;103(17):2171-5. [pmid: 11331258].
71 Matsen SL, Perler BA, Chang DC. A preliminary clinical scale to predict the risk of in-hospital death after carotid endarterectomy. J Vasc Surg. 2005;42(5):861-8. [pmid: 16275438].
72 Mauney MC, Buchanan SA, Lawrence WA, et al. Stroke rate is markedly reduced after carotid endarterectomy by avoidance of protamine. J Vasc Surg. 1995;22(3):264-9. [pmid: 7674469].
73 McBrien K, Rabi DM, Campbell N, et al. Intensive and standard blood pressure targets in patients with type 2 diabetes mellitus: systematic review and meta-analysis. Arch Intern Med. 2012;172(17):1296-303. [pmid: 22868819].
74 McKevitt FM, Sivaguru A, Venables GS, et al. Effect of treatment of carotid artery stenosis on blood pressure: a comparison of hemodynamic disturbances after carotid endarterectomy and endovascular treatment. Stroke. 2003;34(11):2576-81. [pmid: 14593127].
75 Messe SR, Kasner SE, Mehta Z, et al. Effect of body size on operative risk of carotid endarterectomy. J Neurol Neurosurg Psychiatry. 2004;75(12):1759-61. [pmid: 15548500].
76 Mingoli A, Sapienza P, Feldhaus RJ, et al. Carotid endarterectomy in young adults: is it a worthwhile procedure?. J Vasc Surg. 1997;25(3):464-70. [pmid: 9081127].
77 Mocco J, Wilson DA, Komotar RJ, et al. Galbraith Award: evaluation of risk factors associated with neurocognitive changes after carotid endarterectomy. Clin Neurosurg. 2006;53:301-6. [pmid: 17380766].
78 Mocco J, Wilson DA, Komotar RJ, et al. Predictors of neurocognitive decline after carotid endarterectomy. Neurosurgery. 2006;58(5):844-50. [pmid: 16639318].
79 Mommertz G, Das M, Langer S, et al. Early control of distal internal carotid artery during carotid endarterectomy: does it reduce cerebral microemboli?. J Cardiovasc Surg (Torino). 2010;51(3):369-75. [pmid: 20523287].
80 Naylor R, Hayes PD, Payne DA, et al. Randomized trial of vein versus Dacron patching during carotid endarterectomy: long-term results. J Vasc Surg. 2004;39(5):985-93. [pmid: 15111849].
81 Pieniazek P, Musialek P, Kablak-Ziembicka A, et al. Carotid artery stenting with patient- and lesion-tailored selection of the neuroprotection system and stent type: early and 5-year results from a prospective academic registry of 535 consecutive procedures (TARGET-CAS). J Endovasc Ther. 2008;15(3):249-62. [pmid: 18540694].
82 Polak JF, Szklo M, Kronmal RA, et al. The value of carotid artery plaque and intima-media thickness for incident cardiovascular disease: the multi-ethnic study of atherosclerosis. J Am Heart Assoc. 2013;2(2):e000087. [pmid: 23568342].
83 Qureshi AI, Suri MF, New G, et al. Multicenter study of the feasibility and safety of using the memotherm carotid arterial stent for extracranial carotid artery stenosis. J Neurosurg. 2002;96(5):830-6. [pmid: 12005390].
84 Revnic CR, Prada GI, Pena C, et al. Evaluation of total serum MMP-9 and their inhibitors TIMP-1 as a markers of carotid plaque instability in elderly patients with carotid stenosis. Eur J Neurol. 2012;19:181.
85 Robertson L, Ghouri Maaz A, Kovacs F. Antiplatelet and anticoagulant drugs for prevention of restenosis/reocclusion following peripheral endovascular treatment. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2012.
86 Saba L, Sanfilippo R, Anzidei M, et al. Stenosis Asymmetry Index (SAI) between symptomatic and asymptomatic patients in the analysis of carotid arteries. A study using CT angiography. Eur J Radiol. 2012;81(1):77-82. [pmid: 21242044].
87 Sabeti S, Schlager O, Exner M, et al. Progression of carotid stenosis detected by duplex ultrasonography predicts adverse outcomes in cardiovascular high-risk patients. Stroke. 2007;38(11):2887-94. [pmid: 17885257].
88 Sadato A, Satow T, Ishii A, et al. Use of a large angioplasty balloon for predilation is a risk factor for embolic complications in protected carotid stenting. Neurol Med Chir (Tokyo). 2004;44(7):337-42. [pmid: 15347209].
89 Sameshima T, Futami S, Morita Y, et al. Clinical usefulness of and problems with three-dimensional CT angiography for the evaluation of arteriosclerotic stenosis of the carotid artery: comparison with conventional angiography, MRA, and ultrasound sonography. Surg Neurol. 1999;51(3):301-8. [pmid: 10086495].
90 Sandercock PA, Counsell C, Kamal Ayeesha K. Anticoagulants for acute ischaemic stroke. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2008.
91 Sayeed S, Stanziale SF, Wholey MH, et al. Angiographic lesion characteristics can predict adverse outcomes after carotid artery stenting. J Vasc Surg. 2008;47(1):81-7. [pmid: 18178457].
92 Scavee V, Theys S, Schoevaerdts JC. Does retrojugular route for carotid endarterectomy increase the risk of internal jugular vein thrombosis?. Acta Chir Belg. 2006;106(4):397-9. [pmid: 17017691].
93 Self DD, Bryson GL, Sullivan PJ. Risk factors for post-carotid endarterectomy hematoma formation. Can J Anaesth. 1999;46(7):635-40. [pmid: 10442957].
94 Seretis K, Goudakos I, Vlachakis I, et al. Carotid artery disease in octogenarians: endarterectomy or stenting?. (Structured abstract). Int Angiol. 2007:353-60. [pmid: 18091703].
95 Sheikh K, Bullock C. Variation and changes in state-specific carotid endarterectomy and 30-day mortality rates, United States, 1991-2000. J Vasc Surg. 2003;38(4):779-84. [pmid: 14560230].
96 Silvestrini M, Troisi E, Matteis M, et al. Transcranial Doppler assessment of cerebrovascular reactivity in symptomatic and asymptomatic severe carotid stenosis. Stroke. 1996;27(11):1970-3. [pmid: 8898800].
97 Simons JP, Goodney PP, Baril DT, et al. The effect of postoperative stroke and myocardial infarction on long-term survival after carotid revascularization. J Vasc Surg. 2013;57(6):1581-8. [pmid: 23402875].
98 Slovut DP, Romero JM, Hannon KM, et al. Detection of common carotid artery stenosis using duplex ultrasonography: a validation study with computed tomographic angiography. J Vasc Surg. 2010;51(1):65-70. [pmid: 19879097].
99 Staub D, Patel MB, Tibrewala A, et al. Vasa vasorum and plaque neovascularization on contrast-enhanced carotid ultrasound imaging correlates with cardiovascular disease and past cardiovascular events. Stroke. 2010;41(1):41-7. [pmid: 19910551].
100 Steinberg J. Does carotid endarterectomy benefit patients with carotid stenosis but no symptoms?. J Fam Pract. 2000;49(7):600. 55. [pmid: 10923567].
101 Sudlow CL, Mason G, Maurice James B, et al. Thienopyridine derivatives versus aspirin for preventing stroke and other serious vascular events in high vascular risk patients. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2009.
102 Takach TJ, Reul GJ Jr, Cooley DA, et al. Is an integrated approach warranted for concomitant carotid and coronary artery disease?. Ann Thorac Surg. 1997;64(1):16-22. [pmid: 9236329].
103 Taniguchi N, Itoh K, Honda M, et al. Comparative ultrasonographic and angiographic study of carotid arterial lesions in Takayasu's arteritis. Angiology. 1997;48(1):9-20. [pmid: 8995338].
104 Telman G, Kouperberg E, Sprecher E, et al. Duplex ultrasound verified by angiography in patients with severe primary and restenosis of internal carotid artery. Ann Vasc Surg. 2006;20(4):478-81. [pmid: 16642286].
105 Tu JV, Wang H, Bowyer B, et al. Risk factors for death or stroke after carotid endarterectomy: observations from the Ontario Carotid Endarterectomy Registry. Stroke. 2003;34(11):2568-73. [pmid: 14526040].
106 Ungersbock K, Bocher-Schwarz H, Muller-Forell W, et al. The preoperative assessment of stroke risk in lesions involving the internal carotid artery. Br J Neurosurg. 1995;9(4):477-86. [pmid: 7576274].
107 Valentine N, Van de Laar FA, van Driel ML. Adenosine-diphosphate (ADP) receptor antagonists for the prevention of cardiovascular disease in type 2 diabetes mellitus. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2012.
108 Vernieri F, Pasqualetti P, Matteis M, et al. Effect of collateral blood flow and cerebral vasomotor reactivity on the outcome of carotid artery occlusion. Stroke. 2001;32(7):1552-8. [pmid: 11441200].
109 Vikatmaa P, Mitchell D, Jensen LP, et al. Variation in clinical practice in carotid surgery in nine countries 2005-2010. Lessons from VASCUNET and recommendations for the future of national clinical audit. Eur J Vasc Endovasc Surg. 2012;44(1):11-7. [pmid: 22633072].
110 Wardlaw JM, Chappell FM, Stevenson M, et al. Accurate, practical and cost-effective assessment of carotid stenosis in the UK. (Structured abstract). Health Technol Assess Database. 2006;(3):1.
111 Yates GN, Bergamini TM, George SM Jr, et al. Carotid endarterectomy results from a state vascular society. Kentucky Vascular Surgery Society Study Group. Am J Surg. 1997;173(4):342-4. [pmid: 9136793].
112 You Y, Hao Q, Leung T, et al. Detection of the siphon internal carotid artery stenosis: transcranial Doppler versus digital subtraction angiography. J Neuroimaging. 2010;20(3):234-9. [pmid: 19889048].
113 Zanchetti A, Crepaldi G, Bond MG, et al. Different effects of antihypertensive regimens based on fosinopril or hydrochlorothiazide with or without lipid lowering by pravastatin on progression of asymptomatic carotid atherosclerosis: principal results of PHYLLIS--a randomized double-blind trial. Stroke. 2004;35(12):2807-12. [pmid: 15514192].

## Ineligible Screening/Intervention

1 Aldoori MI, Benveniste GL, Baird RN, et al. Asymptomatic carotid murmur: ultrasonic factors influencing outcome. Br J Surg. 1987;74(6):496-9. [pmid: 3300839].
2 Allen BT, Anderson CB, Rubin BG, et al. The influence of anesthetic technique on perioperative complications after carotid endarterectomy. J Vasc Surg. 1994;19(5):834-42. [pmid: 8170037].
3 Al-Mubarak N, Roubin GS, Vitek JJ, et al. Microembolization during carotid stenting with the distal-balloon antiemboli system. Int Angiol. 2002;21(4):344-8. [pmid: 12518114].
4 Bornstein NM, Gur AY, Geyer O, et al. Vasomotor reactivity in the ophthalmic artery: different from or similar to intracerebral vessels?. Eur J Ultrasound. 2000;11(1):1-6. [pmid: 10717507].
5 Can U, Furie KL, Suwanwela N, et al. Transcranial Doppler ultrasound criteria for hemodynamically significant internal carotid artery stenosis based on residual lumen diameter calculated from en bloc endarterectomy specimens. Stroke. 1997;28(10):1966-71. [pmid: 9341705].
6 Cantelmo NL, Gordon JK, Hyde C, et al. The significance of early postoperative duplex studies following carotid endarterectomy. Cardiovasc Surg. 1999;7(3):298-302. [pmid: 10386746].
7 Debrey SM, Yu H, Lynch JK, et al. Diagnostic accuracy of magnetic resonance angiography for internal carotid artery disease: a systematic review and meta-analysis. (Structured abstract). Stroke. 2008:2237-48. [pmid: 18556586].
8 Droste DW, Boehm T, Ritter MA, et al. Benefit of echocontrast-enhanced transcranial arterial color-coded duplex ultrasound. Cerebrovasc Dis. 2005;20(5):332-6. [pmid: 16131802].
9 Droste DW, Jurgens R, Nabavi DG, et al. Echocontrast-enhanced ultrasound of extracranial internal carotid artery high-grade stenosis and occlusion. Stroke. 1999;30(11):2302-6. [pmid: 10548662].
10 Durham CA, Ehlert BA, Agle SC, et al. Role of statin therapy and angiotensin blockade in patients with asymptomatic moderate carotid artery stenosis. Ann Vasc Surg. 2012;26(3):344-52. [pmid: 22285349].
11 Illuminati G, Ricco JB, Greco C, et al. Systematic preoperative coronary angiography and stenting improves postoperative results of carotid endarterectomy in patients with asymptomatic coronary artery disease: a randomised controlled trial. Eur J Vasc Endovasc Surg. 2010;39(2):139-45. [pmid: 20005750].
12 Kallmes DF, Omary RA, Dix JE, et al. Specificity of MR angiography as a confirmatory test of carotid artery stenosis. (Structured abstract). Am J Neuroradiol. 1996:1501-6. [pmid: 8883649].
13 Klotzsch C, Popescu O, Sliwka U, et al. Detection of stenoses in the anterior circulation using frequency-based transcranial color-coded sonography. Ultrasound Med Biol. 2000;26(4):579-84. [pmid: 10856620].
14 Kretz B, Abello N, Astruc K, et al. Influence of the contralateral carotid artery on carotid surgery outcome. Ann Vasc Surg. 2012;26(6):766-74. [pmid: 22717355].
15 Longstreth WT Jr, Shemanski L, Lefkowitz D, et al. Asymptomatic internal carotid artery stenosis defined by ultrasound and the risk of subsequent stroke in the elderly. The Cardiovascular Health Study. Stroke. 1998;29(11):2371-6. [pmid: 9804651].
16 Marcucci G, Accrocca F, Gabrielli R, et al. Complete transposition of carotid bifurcation: can it be an additional risk factor of injury to the cranial nerves during carotid endarterectomy?. Interact Cardiovasc Thorac Surg. 2011;13(5):471-4. [pmid: 21873365].
17 Moll FL, Eikelboom BC, Vermeulen FE, et al. Risk factors in asymptomatic patients with a carotid bruit. Eur J Vasc Surg. 1987;1(1):33-9. [pmid: 3503760].
18 Mracek J, Holeckova I, Chytra I, et al. The impact of general versus local anesthesia on early subclinical cognitive function following carotid endarterectomy evaluated using P3 event-related potentials. Acta Neurochir (Wien). 2012;154(3):433-8. [pmid: 22245975].
19 Pedro LM, Pedro MM, Goncalves I, et al. Computer-assisted carotid plaque analysis: characteristics of plaques associated with cerebrovascular symptoms and cerebral infarction. Eur J Vasc Endovasc Surg. 2000;19(2):118-23. [pmid: 10727359].
20 Pennekamp CW, Tromp SC, Ackerstaff RG, et al. Prediction of cerebral hyperperfusion after carotid endarterectomy with transcranial Doppler. Eur J Vasc Endovasc Surg. 2012;43(4):371-6. [pmid: 22264422].
21 Prati P, Tosetto A, Vanuzzo D, et al. Carotid intima media thickness and plaques can predict the occurrence of ischemic cerebrovascular events. Stroke. 2008;39(9):2470-6. [pmid: 18617662].
22 Regina G, Angiletta D, Impedovo G, et al. Dexamethasone minimizes the risk of cranial nerve injury during CEA. J Vasc Surg. 2009;49(1):99-102. [pmid: 19028044].
23 Schechter MA, Shortell CK, Scarborough JE. Regional versus general anesthesia for carotid endarterectomy: the American College of Surgeons National Surgical Quality Improvement Program perspective. Surgery. 2012;152(3):309-14. [pmid: 22749369].
24 Tang TY, Howarth SP, Miller SR, et al. Comparison of the inflammatory burden of truly asymptomatic carotid atheroma with atherosclerotic plaques contralateral to symptomatic carotid stenosis: an ultra small superparamagnetic iron oxide enhanced magnetic resonance study. J Neurol Neurosurg Psychiatry. 2007;78(12):1337-43. [pmid: 17578854].
25 Wessels T, Harrer JU, Stetter S, et al. Three-dimensional assessment of extracranial Doppler sonography in carotid artery stenosis compared with digital subtraction angiography. Stroke. 2004;35(8):1847-51. [pmid: 15205489].

## Ineligible Comparator

1 AbuRahma AF, Robinson P, Holt SM, et al. Perioperative and late stroke rates of carotid endarterectomy contralateral to carotid artery occlusion: results from a randomized trial. Stroke. 2000;31(7):1566-71. [pmid: 10884455].
2 Aburahma AF, Thiele SP, Wulu JT Jr. Prospective controlled study of the natural history of asymptomatic 60% to 69% carotid stenosis according to ultrasonic plaque morphology. J Vasc Surg. 2002;36(3):437-42. [pmid: 12218962].
3 Arya S, Pipinos II, Garg N, et al. Carotid endarterectomy is superior to carotid angioplasty and stenting for perioperative and long-term results. Vasc Endovascular Surg. 2011;45(6):490-8. [pmid: 21646236].
4 Bagaev E, Pichlmaier AM, Bisdas T, et al. Contralateral internal carotid artery occlusion impairs early but not 30-day stroke rate following carotid endarterectomy. Angiology. 2010;61(7):705-10. [pmid: 20498141].
5 Ballotta E, Da Giau G, Saladini M, et al. Carotid endarterectomy with patch closure versus carotid eversion endarterectomy and reimplantation: a prospective randomized study. Surgery. 1999;125(3):271-9. [pmid: 10076611].
6 Bangalore S, Kumar S, Wetterslev J, et al. Carotid artery stenting vs carotid endarterectomy: meta-analysis and diversity-adjusted trial sequential analysis of randomized trials. (Structured abstract). Arch Neurol. 2011:172-84. [pmid: 20937941].
7 Belcaro G, Laurora G, Cesarone MR, et al. Ultrasonic classification of carotid plaques causing less than 60% stenosis according to ultrasound morphology and events. J Cardiovasc Surg (Torino). 1993;34(4):287-94. [pmid: 8227107].
8 Bergeron P, Becquemin JP, Jausseran JM, et al. Percutaneous stenting of the internal carotid artery: the European CAST I study. Carotid Artery Stent Trial. J Endovasc Surg. 1999;6(2):155-9. [pmid: 10473333].
9 Blackshear JL, Cutlip DE, Roubin GS, et al. Myocardial infarction after carotid stenting and endarterectomy: results from the carotid revascularization endarterectomy versus stenting trial. Circulation. 2011;123(22):2571-8. [pmid: 21606394].
10 Bond R, Rerkasem K, Naylor AR, et al. Systematic review of randomized controlled trials of patch angioplasty versus primary closure and different types of patch materials during carotid endarterectomy (Brief record). J Vasc Surg. 2004:1126-35. [pmid: 15622366].
11 Brahmanandam S, Ding EL, Conte MS, et al. Clinical results of carotid artery stenting compared with carotid endarterectomy. J Vasc Surg. 2008;47(2):343-9. [pmid: 18241758].
12 Brightwell RE, Sherwood RA, Athanasiou T, et al. The neurological morbidity of carotid revascularisation: using markers of cellular brain injury to compare CEA and CAS. Eur J Vasc Endovasc Surg. 2007;34(5):552-60. [pmid: 17719806].
13 Brooks WH, McClure RR, Jones MR, et al. Carotid angioplasty and stenting versus carotid endarterectomy for treatment of asymptomatic carotid stenosis: a randomized trial in a community hospital. Neurosurgery. 2004;54(2):318-24. [pmid: 14744277].
14 Cao P, Giordano G, De Rango P, et al. A randomized study on eversion versus standard carotid endarterectomy: study design and preliminary results: the Everest Trial. J Vasc Surg. 1998;27(4):595-605. [pmid: 9576071].
15 Counsell CE, Salinas R, Naylor R, et al. A systematic review of the randomised trials of carotid patch angioplasty in carotid endarterectomy. Eur J Vasc Endovasc Surg. 1997;13(4):345-54. [pmid: 9133984].
16 Dardik H, Wolodiger F, Silvestri F, et al. Clinical experience with everted cervical vein as patch material after carotid endarterectomy. J Vasc Surg. 1997;25(3):545-53. [pmid: 9081137].
17 De Rango P, Lenti M, Simonte G, et al. No benefit from carotid intervention in fatal stroke prevention for >80-year-old patients. Eur J Vasc Endovasc Surg. 2012;44(3):252-9. [pmid: 22819739].
18 De Rango P, Verzini F, Cao P, et al. Carotid revascularization provides similar outcomes in symptomatic and asymptomatic patients with <70 years. Stroke. 2012;43(2).
19 Debing E, Van den Brande P. Chronic renal insufficiency and risk of early mortality in patients undergoing carotid endarterectomy. Ann Vasc Surg. 2006;20(5):609-13. [pmid: 16741650].
20 Dorigo W, Pulli R, Pratesi G, et al. Early and long-term results of carotid endarterectomy in diabetic patients. J Vasc Surg. 2011;53(1):44-52. [pmid: 21050697].
21 Dumont TM, Rughani AI. National trends in carotid artery revascularization surgery. J Neurosurg. 2012;116(6):1251-7. [pmid: 22482791].
22 Economopoulos KP, Sergentanis TN, Tsivgoulis G, et al. Carotid artery stenting versus carotid endarterectomy: a comprehensive meta-analysis of short-term and long-term outcomes. (Structured abstract). Stroke. 2011:687-92. [pmid: 21233476].
23 Erzurum VZ, Littooy FN, Steffen G, et al. Outcome of nonoperative management of asymptomatic high-grade carotid stenosis. J Vasc Surg. 2002;36(4):663-7. [pmid: 12368722].
24 Estes JM, Guadagnoli E, Wolf R, et al. The impact of cardiac comorbidity after carotid endarterectomy. J Vasc Surg. 1998;28(4):577-84. [pmid: 9786249].
25 Faggioli GL, Ferri M, Gargiulo M, et al. A series of 214 carotid stenting procedures: selection criteria, results and potential predictors of success. Ital J Vasc Endovasc Surg. 2006;13(4):167-72.
26 Felli MM, Alunno A, Castiglione A, et al. CEA versus CAS: short-term and mid-term results. Int Angiol. 2012;31(5):420-6. [pmid: 22990503].
27 Fiehler J, Jansen O, Berger J, et al. Differences in complication rates among the centres in the SPACE study. Neuroradiology. 2008:1049-53. [pmid: 18810400].
28 Forbes TL. Preliminary results of carotid revascularization endarterectomy vs stenting trial (CREST). J Vasc Surg. 2010;51(5):1300-1. [pmid: 20420982].
29 Gasparini D, Piccoli G. Extracranial stenting. Cardiovasc Intervent Radiol. 2011;34:485-6.
30 Gossetti B, Gattuso R, Irace L, et al. Embolism to the brain during carotid stenting and surgery. Acta Chir Belg. 2007;107(2):151-4. [pmid: 17515263].
31 Gould DA, Birkmeyer JD. Efficacy versus effectiveness of carotid endarterectomy. Eff Clin Pract. 1999;2(1):30-6. [pmid: 10346551].
32 Gray WA, Hopkins LN, Yadav S, et al. Protected carotid stenting in high-surgical-risk patients: the ARCHeR results. J Vasc Surg. 2006;44(2):258-68. [pmid: 16890850].
33 Gurm HS, Yadav JS, Fayad P, et al. Long-term results of carotid stenting versus endarterectomy in high-risk patients. N Engl J Med. 2008;358(15):1572-9. [pmid: 18403765].
34 Handa N, Matsumoto M, Maeda H, et al. Ischemic stroke events and carotid atherosclerosis. Results of the Osaka Follow-up Study for Ultrasonographic Assessment of Carotid Atherosclerosis (the OSACA Study). Stroke. 1995;26(10):1781-6. [pmid: 7570725].
35 Holloway RG Jr, Witter DM Jr, Mushlin AI, et al. Carotid endarterectomy trends in the patterns and outcomes of care at academic medical centers, 1990 through 1995. Arch Neurol. 1998;55(1):25-32. [pmid: 9443708].
36 Howard VJ, Lutsep HL, Mackey A, et al. Influence of sex on outcomes of stenting versus endarterectomy: a subgroup analysis of the Carotid Revascularization Endarterectomy versus Stenting Trial (CREST). Lancet Neurol. 2011;10(6):530-7. [pmid: 21550314].
37 Jackson RS, Sidawy AN, Amdur RL, et al. Obesity is an independent risk factor for death and cardiac complications after carotid endarterectomy. J Am Coll Surg. 2012;214(2):148-55. [pmid: 22192895].
38 Jeng JS, Liu HM, Tu YK. Carotid angioplasty with or without stenting versus carotid endarterectomy for carotid artery stenosis: a meta-analysis. (Structured abstract). J Neurol Sci. 2008:40-7. [pmid: 18304582].
39 Jordan WD Jr, Voellinger DC, Fisher WS, et al. A comparison of carotid angioplasty with stenting versus endarterectomy with regional anesthesia. J Vasc Surg. 1998;28(3):397-402. [pmid: 9737448].
40 Kakkos SK, Nicolaides AN, Griffin M, et al. Factors associated with mortality in patients with asymptomatic carotid stenosis: results from the ACSRS study. Int Angiol. 2005;24(3):221-30. [pmid: 16158030].
41 Kanter MC, Tegeler CH, Pearce LA, et al. Carotid stenosis in patients with atrial fibrillation. Prevalence, risk factors, and relationship to stroke in the Stroke Prevention in Atrial Fibrillation Study. Arch Intern Med. 1994;154(12):1372-7. [pmid: 8002689].
42 Kapral MK, Wang H, Austin PC, et al. Sex differences in carotid endarterectomy outcomes: results from the Ontario Carotid Endarterectomy Registry. Stroke. 2003;34(5):1120-5. [pmid: 12690225].
43 Kasirajan K, Matteson B, Marek JM, et al. Comparison of nonneurological events in high-risk patients treated by carotid angioplasty versus endarterectomy. Am J Surg. 2003;185(4):301-4. [pmid: 12657378].
44 Kastrup A, Groschel K, Nagele T, et al. Effects of age and symptom status on silent ischemic lesions after carotid stenting with and without the use of distal filter devices. Am J Neuroradiol. 2008;29(3):608-12. [pmid: 18065503].
45 Kastrup A, Schulz JB, Raygrotzki S, et al. Comparison of angioplasty and stenting with cerebral protection versus endarterectomy for treatment of internal carotid artery stenosis in elderly patients. J Vasc Surg. 2004;40(5):945-51. [pmid: 15557909].
46 Kazmers AE. Caroltid surgery in octogenarians in Veterans Affairs medical centers. J Surg Res. 1999;81.
47 Khatri R, Chaudhry SA, Vazquez G, et al. Age differential between outcomes of carotid angioplasty and stent placement and carotid endarterectomy in general practice. J Vasc Surg. 2012;55(1):72-8. [pmid: 22070935].
48 Lanska DJ, Kryscio RJ. In-hospital mortality following carotid endarterectomy. Neurology. 1998;51(2):440-7. [pmid: 9710016].
49 Liu Z, Shi Z, Wang Y, et al. Carotid artery stenting versus carotid endarterectomy: systematic review and meta-analysis. (Structured abstract). World J Surg. 2009:586-96. [pmid: 19127380].
50 Luebke T, Aleksic M, Brunkwall J. Meta-analysis of randomized trials comparing carotid endarterectomy and endovascular treatment. (Structured abstract). Eur J Vasc Endovasc Surg. 2007:470-9. [pmid: 17683960].
51 Madani A, Beletsky V, Tamayo A, et al. High-risk asymptomatic carotid stenosis: ulceration on 3D ultrasound vs TCD microemboli. Neurology. 2011;77(8):744-50. [pmid: 21849642].
52 Magnan PE, Caus T, Branchereau A, et al. Internal carotid artery surgery: ten-year results. Ann Vasc Surg. 1993;7(6):521-9. [pmid: 8123454].
53 Mantese VA, Timaran CH, Chiu D, et al. The Carotid Revascularization Endarterectomy versus Stenting Trial (CREST): stenting versus carotid endarterectomy for carotid disease. Stroke. 2010;41(10 Suppl):S31-4. [pmid: 20876500].
54 Mathiesen EB, Johnsen SH, Wilsgaard T, et al. Carotid plaque area and intima-media thickness in prediction of first-ever ischemic stroke: a 10-year follow-up of 6584 men and women: the Tromso Study. Stroke. 2011;42(4):972-8. [pmid: 21311059].
55 Mattos MA, Barkmeier LD, Hodgson KJ, et al. Internal carotid artery occlusion: operative risks and long-term stroke rates after contralateral carotid endarterectomy. Surgery. 1992;112(4):670-9. [pmid: 1411937].
56 Maxwell JG, Rutledge R, Covington DL, et al. A statewide, hospital-based analysis of frequency and outcomes in carotid endarterectomy. Am J Surg. 1997;174(6):655-60. [pmid: 9409592].
57 Meier P, Knapp G, Tamhane U, et al. Short term and intermediate term comparison of endarterectomy versus stenting for carotid artery stenosis: systematic review and meta-analysis of randomised controlled clinical trials. (Structured abstract). BMJ. 2010.
58 Miller MT, Comerota AJ, Tzilinis A, et al. Carotid endarterectomy in octogenarians: does increased age indicate “high risk?”. J Vasc Surg. 2005;41(2):231-7. [pmid: 15768004].
59 Montauban van Swijndregt AD, Elbers HR, Moll FL, et al. Cerebral ischemic disease and morphometric analyses of carotid plaques. Ann Vasc Surg. 1999;13(5):468-74. [pmid: 10466989].
60 Mostaza JM, Gonzalez-Juanatey JR, Castillo J, et al. Prevalence of carotid stenosis and silent myocardial ischemia in asymptomatic subjects with a low ankle-brachial index. J Vasc Surg. 2009;49(1):104-8. [pmid: 18829225].
61 Murad MH, Flynn DN, Elamin MB, et al. Endarterectomy vs stenting for carotid artery stenosis: a systematic review and meta-analysis. (Structured abstract). J Vasc Surg. 2008:487-93. [pmid: 18644495].
62 Murad MH, Shahrour A, Shah ND, et al. A systematic review and meta-analysis of randomized trials of carotid endarterectomy vs stenting. (Structured abstract). J Vasc Surg. 2011:792-7. [pmid: 21216556].
63 Nonent M, Serfaty JM, Nighoghossian N, et al. Concordance rate differences of 3 noninvasive imaging techniques to measure carotid stenosis in clinical routine practice: results of the CARMEDAS multicenter study. Stroke. 2004;35(3):682-6. [pmid: 14764932].
64 Parlani G, De Rango P, Cieri E, et al. Diabetes is not a predictor of outcome for carotid revascularization with stenting as it may be for carotid endarterectomy. J Vasc Surg. 2012;55(1):79-89. [pmid: 22056251].
65 Pemberton M, Reid A, London NJ, et al. Carotid endarterectomy is safe in selected elderly patients. Br J Surg. 1998;85(4):507. [pmid: 9607533].
66 Perler BA, Dardik A, Burleyson GP, et al. Influence of age and hospital volume on the results of carotid endarterectomy: a statewide analysis of 9918 cases. J Vasc Surg. 1998;27(1):25-31. [pmid: 9474079].
67 Pinkerton JJ, Gholkar VR. Should patient age be a consideration in carotid endarterectomy. J Vasc Surg. 1990;11(5).
68 Plecha EJ, King TA, Pitluk HC, et al. Risk assessment in patients undergoing carotid endarterectomy. Cardiovasc Surg. 1993;1(1):30-2. [pmid: 8075992].
69 Qureshi AI, Kirmani JF, Divani AA, et al. Carotid angioplasty with or without stent placement versus carotid endarterectomy for treatment of carotid stenosis: a meta-analysis. (Structured abstract). Neurosurgery. 2005:1171-9. [pmid: 15918933].
70 Rerkasem K, Rothwell PM. Systematic review of randomized controlled trials of patch angioplasty versus primary closure during carotid endarterectomy (Brief record). Stroke. 2010:e55-6.
71 Rigdon EE, Monajjem N, Rhodes RS. Is carotid endarterectomy justified in patients with severe chronic renal insufficiency?. Ann Vasc Surg. 1997;11(2):115-9. [pmid: 9181764].
72 Riles TS, Lee V, Cheever D, et al. Clinical course of asymptomatic patients with carotid duplex scan end diastolic velocities of 100 to 124 centimeters per second. J Vasc Surg. 2010;52(4):914-9. [pmid: 20630689].
73 Rothwell PM, Slattery J, Warlow CP. A systematic comparison of the risks of stroke and death due to carotid endarterectomy for symptomatic and asymptomatic stenosis. (Structured abstract). Stroke. 1996:266-9. [pmid: 8571421].
74 Rudarakanchana N, Dialynas M, Halliday A. Asymptomatic Carotid Surgery Trial-2 (ACST-2): rationale for a randomised clinical trial comparing carotid endarterectomy with carotid artery stenting in patients with asymptomatic carotid artery stenosis. Eur J Vasc Endovasc Surg. 2009;38(2):239-42. [pmid: 19540137].
75 Saba L, Sanfilippo R, Montisci R, et al. Correlation between US-PSV and MDCTA in the quantification of carotid artery stenosis. Eur J Radiol. 2010;74(1):99-103. [pmid: 19246169].
76 Schneider EB, Black JH 3rd, Hambridge HL, et al. The impact of race and ethnicity on the outcome of carotid interventions in the United States. J Surg Res. 2012;177(1):172-7. [pmid: 22459294].
77 Sheffet AJ, Roubin G, Howard G, et al. Design of the Carotid Revascularization Endarterectomy vs. Stenting Trial (CREST). Int J Stroke. 2010;5(1):40-6. [pmid: 20088993].
78 Siebler M, Nachtmann A, Sitzer M, et al. Cerebral microembolism and the risk of ischemia in asymptomatic high-grade internal carotid artery stenosis. Stroke. 1995;26(11):2184-6. [pmid: 7482670].
79 Stanziale SF, Marone LK, Boules TN, et al. Carotid artery stenting in octogenarians is associated with increased adverse outcomes. J Vasc Surg. 2006;43(2):297-304. [pmid: 16476605].
80 Steinke W, Meairs S, Ries S, et al. Sonographic assessment of carotid artery stenosis. Comparison of power Doppler imaging and color Doppler flow imaging. Stroke. 1996;27(1):91-4. [pmid: 8553411].
81 Stukenborg GJ. Comparison of carotid endarterectomy outcomes from randomized controlled trials and Medicare administrative databases. Arch Neurol. 1997;54(7):826-32. [pmid: 9236570].
82 Theiss W, Hermanek P, Mathias K, et al. Pro-CAS: a prospective registry of carotid angioplasty and stenting. Stroke. 2004;35(9):2134-9. [pmid: 15232119].
83 Touze E, Trinquart L, Chatellier G, et al. Systematic review of the perioperative risks of stroke or death after carotid angioplasty and stenting. (Structured abstract). Stroke. 2009:e683-93. [pmid: 19892997].
84 Usman AA, Tang GL, Eskandari MK. Metaanalysis of procedural stroke and death among octogenarians: carotid stenting versus carotid endarterectomy. J Am Coll Surg. 2009;208(6):1124-31. [pmid: 19476901].
85 Warlow CP, Bodenham AR, Colam B, et al. General anaesthesia versus local anaesthesia for carotid surgery (GALA): a multicentre, randomised controlled trial. Lancet. 2008;372(9656):2132-42. [pmid: 19041130].
86 White RA, Sicard GA, Zwolak RM, et al. Society of vascular surgery vascular registry comparison of carotid artery stenting outcomes for atherosclerotic vs nonatherosclerotic carotid artery disease. J Vasc Surg. 2010;51(5):1116-23. [pmid: 20347551].
87 Wiesmann M, Schopf V, Jansen O, et al. Stent-protected angioplasty versus carotid endarterectomy in patients with carotid artery stenosis: meta-analysis of randomized trial data. (Structured abstract). Eur Radiol. 2008:2956-66. [pmid: 18654784].
88 Yavin D, Roberts DJ, Tso M, et al. Carotid endarterectomy versus stenting: a meta-analysis of randomized trials. (Structured abstract). Can J Neurol Sci. 2011:230-5. [pmid: 21320825].
89 Yeh RW, Kennedy K, Spertus JA, et al. Do postmarketing surveillance studies represent real-world populations? A comparison of patient characteristics and outcomes after carotid artery stenting. Circulation. 2011;123(13):1384-90. [pmid: 21422383].
90 Zahn R, Hochadel M, Grau A, et al. Stent-supported angioplasty versus endarterectomy for carotid artery stenosis: evidence from current randomized trials. (Structured abstract). Z Kardiol. 2005:836-43. [pmid: 16382386].

## Ineligible Outcome

1 Adachi T, Takagi M, Hoshino H, et al. Effect of extracranial carotid artery stenosis and other risk factors for stroke on periventricular hyperintensity. Stroke. 1997;28(11):2174-9. [pmid: 9368560].
2 Beijers HJ, Henry RM, Bravenboer B, et al. Metabolic syndrome in nondiabetic individuals associated with maladaptive carotid remodeling: the Hoorn Study. Am J Hypertens. 2011;24(4):429-36. [pmid: 21212746].
3 Bicknell CD, Cowling MG, Clark MW, et al. Carotid angioplasty in a pulsatile flow model: factors affecting embolic potential. Eur J Vasc Endovasc Surg. 2003;26(1):22-31. [pmid: 12819644].
4 Cohen SN, Hobson RW 2nd, Weiss DG, et al. Death associated with asymptomatic carotid artery stenosis: long-term clinical evaluation. VA Cooperative Study 167 Group. J Vasc Surg. 1993;18(6):1002-9. [pmid: 8264028].
5 Comerota AJ, Salles-Cunha SX, Daoud Y, et al. Gender differences in blood velocities across carotid stenoses. J Vasc Surg. 2004;40(5):939-44. [pmid: 15557908].
6 Cote R, Battista RN, Abrahamowicz M, et al. Lack of effect of aspirin in asymptomatic patients with carotid bruits and substantial carotid narrowing. The Asymptomatic Cervical Bruit Study Group. Ann Intern Med. 1995;123(9):649-55. [pmid: 7574219].
7 Cuspidi C, Meani S, Valerio C, et al. Carotid atherosclerosis and cardiovascular risk stratification: role and cost-effectiveness of echo-Doppler examination in untreated essential hypertensives. Blood Press. 2006;15(6):333-9. [pmid: 17472023].
8 Deriu GP, Milite D, Damiani N, et al. Carotid endarterectomy without angiography: a prospective randomised pilot study. Eur J Vasc Endovasc Surg. 2000;20(3):250-3. [pmid: 10986023].
9 Feasby TE, Quan H, Ghali WA. Provincial carotid endarterectomy outcomes. Can J Neurol Sci. 2002;29(4):333-6. [pmid: 12463488].
10 Fried LP, Borhani NO, Enright P, et al. The Cardiovascular Health Study: design and rationale. Ann Epidemiol. 1991;1(3):263-76. [pmid: 1669507].
11 Hartmann A, Mast H, Thompson JL, et al. Transcranial Doppler waveform blunting in severe extracranial carotid artery stenosis. Cerebrovasc Dis. 2000;10(1):33-8. [pmid: 10629344].
12 Heliopoulos J, Vadikolias K, Piperidou C, et al. Detection of carotid artery plaque ulceration using 3-dimensional ultrasound. J Neuroimaging. 2011;21(2):126-31. [pmid: 19888925].
13 Heyman A, Wilkinson WE, Heyden S, et al. Risk of stroke in asymptomatic persons with cervical arterial bruits: a population study in Evans County, Georgia. N Engl J Med. 1980;302(15):838-41. [pmid: 7360161].
14 Horn J, Naylor AR, Laman DM, et al. Identification of patients at risk for ischaemic cerebral complications after carotid endarterectomy with TCD monitoring. Eur J Vasc Endovasc Surg. 2005;30(3):270-4. [pmid: 15963744].
15 Kardoulas DG, Katsamouris AN, Gallis PT, et al. Ultrasonographic and histologic characteristics of symptom-free and symptomatic carotid plaque. Cardiovasc Surg. 1996;4(5):580-90. [pmid: 8909814].
16 Kim SH, Kim YM, Cho MA, et al. Echogenic carotid artery plaques are associated with vertebral fractures in postmenopausal women with low bone mass. Calcif Tissue Int. 2008;82(6):411-7. [pmid: 18496724].
17 Lal BK, Brott TG. The Carotid Revascularization Endarterectomy vs. Stenting Trial completes randomization: lessons learned and anticipated results. J Vasc Surg. 2009;50(5):1224-31. [pmid: 19878793].
18 Lind L, Andersson J, Hansen T, et al. Atherosclerosis measured by whole body magnetic resonance angiography and carotid artery ultrasound is related to arterial compliance, but not to endothelium-dependent vasodilation. The Prospective Investigation of the Vasculature in Uppsala Seniors (PIVUS) study. Clin Physiol Funct Imaging. 2009;29(5):321-9. [pmid: 19486081].
19 Loncar R, Muller BT, Zotz RB, et al. The screening power of methylenetetrahydrofolate reductase C677T polymorphism versus plasma homocysteine concentration in patients with stenosis of the internal carotid artery. Thromb J. 2006;4:16. [pmid: 16999862].
20 Mackinnon AD, Aaslid R, Markus HS. Ambulatory transcranial Doppler cerebral embolic signal detection in symptomatic and asymptomatic carotid stenosis. Stroke. 2005;36(8):1726-30. [pmid: 16040594].
21 Markus H. The Asymptomatic Carotid Emboli Study: study design and baseline results. Int J Stroke. 2009;4(5):398-405. [pmid: 19765130].
22 Newman AB, Naydeck BL, Ives DG, et al. Coronary artery calcium, carotid artery wall thickness, and cardiovascular disease outcomes in adults 70 to 99 years old. Am J Cardiol. 2008;101(2):186-92. [pmid: 18178404].
23 Rajeswaran D, Saunder A, Raymond S. Post-operative risk factor control following internal carotid artery intervention. ANZ J Surg. 2011;81(11):817-21. [pmid: 22295407].
24 Reiff T, Stingele R, Eckstein HH, et al. Stent-protected angioplasty in asymptomatic carotid artery stenosis vs. endarterectomy: SPACE2--a three-arm randomised-controlled clinical trial. Int J Stroke. 2009;4(4):294-9. [pmid: 19689759].
25 Robless P, Emson M, Thomas D, et al. Are we detecting and operating on high risk patients in the asymptomatic carotid surgery trial? The Asymptomatic Carotid Surgery Trial Collaborators. Eur J Vasc Endovasc Surg. 1998;16(1):59-64. [pmid: 9715718].
26 Takahashi W, Ohnuki T, Honma K, et al. The significance of multiple risk factors for early carotid atherosclerosis in Japanese subjects. Intern Med. 2007;46(20):1679-84. [pmid: 17938520].
27 Tell GS, Fried LP, Hermanson B, et al. Recruitment of adults 65 years and older as participants in the Cardiovascular Health Study. Ann Epidemiol. 1993;3(4):358-66. [pmid: 8275211].
28 Voeks JH, Howard G, Roubin GS, et al. Age and outcomes after carotid stenting and endarterectomy: the carotid revascularization endarterectomy versus stenting trial. Stroke. 2011;42(12):3484-90. [pmid: 21980205].
29 Wallaert JB, Cronenwett JL, Bertges DJ, et al. Optimal selection of asymptomatic patients for carotid endarterectomy based on predicted 5-year survival. J Vasc Surg. 2013;58(1):112-8. [pmid: 23478502].
30 Wiebers DO, Whisnant JP, Sandok BA, et al. Prospective comparison of a cohort with asymptomatic carotid bruit and a population-based cohort without carotid bruit. Stroke. 1990;21(7):984-8. [pmid: 2368113].
31 Yoshimura S, Kawasaki M, Yamada K, et al. Visualization of internal carotid artery atherosclerotic plaques in symptomatic and asymptomatic patients: a comparison of optical coherence tomography and intravascular ultrasound. AJNR Am J Neuroradiol. 2012;33(2):308-13. [pmid: 22051806].

## Ineligible Setting

1 Kakkos SK, Sabetai M, Tegos T, et al. Silent embolic infarcts on computed tomography brain scans and risk of ipsilateral hemispheric events in patients with asymptomatic internal carotid artery stenosis. J Vasc Surg. 2009;49(4):902-9. [pmid: 19223148].
2 Yurdakul M, Tola M, Cumhur T. B-flow imaging of internal carotid artery stenosis: comparison with power Doppler imaging and digital subtraction angiography. J Clin Ultrasound. 2004;32(5):243-8. [pmid: 15124191].

## Ineligible Study Design

1 Risk of stroke in the distribution of an asymptomatic carotid artery. The European Carotid Surgery Trialists Collaborative Group. Lancet. 1995;345(8944):209-12. [pmid: 7823712].
2 Abbott AL. Medical (nonsurgical) intervention alone is now best for prevention of stroke associated with asymptomatic severe carotid stenosis: results of a systematic review and analysis. Stroke. 2009;40(10):e573-83. [pmid: 19696421].
3 Abbott AL, Chambers BR, Stork JL, et al. Embolic signals and prediction of ipsilateral stroke or transient ischemic attack in asymptomatic carotid stenosis: a multicenter prospective cohort study. Stroke. 2005;36(6):1128-33. [pmid: 15879327].
4 AbuRahma AF, Metz MJ, Robinson PA. Natural history of ≥60% asymptomatic carotid stenosis in patients with contralateral carotid occlusion. Ann Surg. 2003;238(4):551-61. [pmid: 14530726].
5 AbuRahma AF, Srivastava M, Chong B, et al. Impact of chronic renal insufficiency using serum creatinine vs glomerular filtration rate on perioperative clinical outcomes of carotid endarterectomy. J Am Coll Surg. 2013;216(4):525-32. [pmid: 23403138].
6 Ackerstaff RG, Vos JA. TCD-detected cerebral embolism in carotid endarterectomy versus angioplasty and stenting of the carotid bifurcation. Acta Chir Belg. 2004;104(1):55-9. [pmid: 15053466].
7 Ackerstaff RG. Transcranial Doppler monitoring in angioplasty and stenting of the carotid bifurcation. J Endovasc Ther. 2003;10(4):702-10. [pmid: 14533974].
8 Adler Y, Levinger U, Koren A, et al. Relation of nonobstructive aortic valve calcium to carotid arterial atherosclerosis. Am J Cardiol. 2000;86(10):1102-5. [pmid: 11074207].
9 Andrawes WF, Bussy C, Belmin J. Prevention of cardiovascular events in elderly people. Drugs Aging. 2005;22(10):859-76. [pmid: 16245959].
10 Appleberg M, Cottier D, Crozier J, et al. Carotid endarterectomy for asymptomatic carotid artery stenosis: patients with severe bilateral disease a high risk subgroup. Aust N Z J Surg. 1995;65(3):160-5. [pmid: 7887857].
11 Ascher E, Hingorani A, Gunduz Y, et al. Posterior transverse plication technique for treatment of redundant internal carotid artery during endarterectomy. Cardiovasc Surg. 2001;9(1):16-9. [pmid: 11137803].
12 Back MR, Rogers GA, Wilson JS, et al. Magnetic resonance angiography minimizes need for arteriography after inadequate carotid duplex ultrasound scanning. J Vasc Surg. 2003;38(3):422-30. [pmid: 12947246].
13 Balestrini S, Lupidi F, Balucani C, et al. One-year progression of moderate asymptomatic carotid stenosis predicts the risk of vascular events. Stroke. 2013;44(3):792-4. [pmid: 23287778].
14 Ballotta E, Da Giau G, Abbruzzese E, et al. Carotid endarterectomy without angiography: can clinical evaluation and duplex ultrasonographic scanning alone replace traditional arteriography for carotid surgery workup? A prospective study. Surgery. 1999;126(1):20-7. [pmid: 10418588].
15 Ballotta E, Meneghetti G, Manara R, et al. Long-term survival and stroke-free survival after eversion carotid endarterectomy for asymptomatic severe carotid stenosis. J Vasc Surg. 2007;46(2):265-70. [pmid: 17600662].
16 Bertges DJ, Goodney PP, Zhao Y, et al. The Vascular Study Group of New England Cardiac Risk Index (VSG-CRI) predicts cardiac complications more accurately than the Revised Cardiac Risk Index in vascular surgery patients. J Vasc Surg. 2010;52(3):674-83. [pmid: 20570467].
17 Bisdas T, Egorova N, Moskowitz AJ, et al. The impact of gender on in-hospital outcomes after carotid endarterectomy or stenting. Eur J Vasc Endovasc Surg. 2012;44(3):244-50. [pmid: 22819738].
18 Bots ML, Breslau PJ, Briet E, et al. Cardiovascular determinants of carotid artery disease. The Rotterdam Elderly Study. Hypertension. 1992;19(6 Pt 2):717-20. [pmid: 1592472].
19 Boules TN, Proctor MC, Aref A, et al. Carotid endarterectomy remains the standard of care, even in high-risk surgical patients. Ann Surg. 2005;241(2):356-63. [pmid: 15650648].
20 Brajovic MD, Markovic N, Loncar G, et al. The influence of various morphologic and hemodynamic carotid plaque characteristics on neurological events onset and deaths. Sci World J. 2009;9:509-21.
21 Bunch CT, Kresowik TF. Can randomized trial outcomes for carotid endarterectomy be achieved in community-wide practice?. Semin Vasc Surg. 2004;17(3):209-13. [pmid: 15449242].
22 Buszman PP, Szymanski R, Debinski M, et al. Long-term results of cephalad arteries percutanoeus transluminal angioplasty with stent implantation (the CAPTAS registry). Catheter Cardiovasc Interv. 2012;79(4):532-40. [pmid: 22311860].
23 Calvillo-King L, Xuan L, Zhang S, et al. Predicting risk of perioperative death and stroke after carotid endarterectomy in asymptomatic patients: derivation and validation of a clinical risk score. Stroke. 2010;41(12):2786-94. [pmid: 21051669].
24 Cao P, Giordano G, De Rango P, et al. Computerised tomography findings as a risk factor in carotid endarterectomy: early and late results. Eur J Vasc Endovasc Surg. 1996;12(1):37-45. [pmid: 8696895].
25 Cao P, Zannetti S, Giordano G, et al. Cerebral tomographic findings in patients undergoing carotid endarterectomy for asymptomatic carotid stenosis: short-term and long-term implications. J Vasc Surg. 1999;29(6):995-1005. [pmid: 10359933].
26 Caracci BF, Zukowski AJ, Hurley JJ, et al. Asymptomatic severe carotid stenosis. J Vasc Surg. 1989;9(2):361-6. [pmid: 2645445].
27 Chaves C, Hreib K, Allam G, et al. Patterns of cerebral perfusion in patients with asymptomatic internal carotid artery disease. Cerebrovasc Dis. 2006;22(5-6):396-401. [pmid: 16888382].
28 Cinat ME, Casalme C, Wilson SE, et al. Computed tomography angiography validates duplex sonographic evaluation of carotid artery stenosis. Am Surg. 2003;69(10):842-7. [pmid: 14570360].
29 Coe DA, Towne JB, Seabrook GR, et al. Duplex morphologic features of the reconstructed carotid artery: changes occurring more than five years after endarterectomy. J Vasc Surg. 1997;25(5):850-6. [pmid: 9152312].
30 Dalainas I, Nano G, Bianchi P, et al. Carotid endarterectomy in patients with contralateral carotid artery occlusion. Ann Vasc Surg. 2007;21(1):16-22. [pmid: 17349330].
31 Dardik A, Bowman HM, Gordon TA, et al. Impact of race on the outcome of carotid endarterectomy: a population-based analysis of 9,842 recent elective procedures. Ann Surg. 2000;232(5):704-9. [pmid: 11066143].
32 de Donato G, Setacci C, Deloose K, et al. Long-term results of carotid artery stenting. J Vasc Surg. 2008;48(6):1431-40. [pmid: 18848755].
33 Debing E, Aerden D, Van den Brande P. Diabetes mellitus is a predictor for early adverse outcome after carotid endarterectomy. Vasc Endovascular Surg. 2011;45(1):28-32. [pmid: 21156716].
34 Debing E, Van den Brande P. Carotid endarterectomy in the elderly: are the patient characteristics, the early outcome, and the predictors the same as those in younger patients?. Surg Neurol. 2007;67(5):467-71. [pmid: 17445605].
35 den Hartog AG, Achterberg S, Moll FL, et al. Asymptomatic carotid artery stenosis and the risk of ischemic stroke according to subtype in patients with clinical manifest arterial disease. Stroke. 2013;44(4):1002-7. [pmid: 23404720].
36 Duschek N, Ghai S, Sejkic F, et al. Homocysteine improves risk stratification in patients undergoing endarterectomy for asymptomatic internal carotid artery stenosis. Stroke. 2013;44(8):2311-4. [pmid: 23760214].
37 Eldrup N, Gronholdt ML, Sillesen H, et al. Elevated matrix metalloproteinase-9 associated with stroke or cardiovascular death in patients with carotid stenosis. Circulation. 2006;114(17):1847-54. [pmid: 17030690].
38 Fine-Edelstein JS, Wolf PA, O'Leary DH, et al. Precursors of extracranial carotid atherosclerosis in the Framingham study. Neurology. 1994;44(6):1046-50. [pmid: 8208397].
39 Finocchi C, Gandolfo C, Carissimi T, et al. Role of transcranial Doppler and stump pressure during carotid endarterectomy. Stroke. 1997;28(12):2448-52. [pmid: 9412630].
40 Flanigan DP, Flanigan ME, Dorne AL, et al. Long-term results of 442 consecutive, standardized carotid endarterectomy procedures in standard-risk and high-risk patients. J Vasc Surg. 2007;46(5):876-82. [pmid: 17980273].
41 Folkersen L, Persson J, Ekstrand J, et al. Prediction of ischemic events on the basis of transcriptomic and genomic profiling in patients undergoing carotid endarterectomy. Mol Med. 2012;18:669-75. [pmid: 22371308].
42 Frawley JE, Hicks RG, Woodforth IJ. Risk factors for peri-operative stroke complicating carotid endarterectomy: selective analysis of a prospective audit of 1000 consecutive operations. Aust N Z J Surg. 2000;70(1):52-6. [pmid: 10696944].
43 Furst H, Hartl WH, Haberl R, et al. Silent cerebral infarction: risk factor for stroke complicating carotid endarterectomy. World J Surg. 2001;25(8):969-74. [pmid: 11571977].
44 Garvey L, Makaroun MS, Muluk VS, et al. Etiologic factors in progression of carotid stenosis: a 10-year study in 905 patients. J Vasc Surg. 2000;31(1 Pt 1):31-8. [pmid: 10642706].
45 Goldstein LB, Samsa GP, Matchar DB, et al. Multicenter review of preoperative risk factors for endarterectomy for asymptomatic carotid artery stenosis. Stroke. 1998;29(4):750-3. [pmid: 9550506].
46 Goliasch G, Schillinger M, Mayer FJ, et al. Usefulness of hemoglobin level to predict long-term mortality in patients with asymptomatic carotid narrowing by ultrasonography. Am J Cardiol. 2012;110(11):1699-703. [pmid: 22921994].
47 Greco G, Egorova NN, Moskowitz AJ, et al. A model for predicting the risk of carotid artery disease. Ann Surg. 2013;257(6):1168-73. [pmid: 23333880].
48 Griewing B, Morgenstern C, Driesner F, et al. Cerebrovascular disease assessed by color-flow and power Doppler ultrasonography. Comparison with digital subtraction angiography in internal carotid artery stenosis. Stroke. 1996;27(1):95-100. [pmid: 8553412].
49 Grizzell BE, Ammar AD, Helmer SD. Carotid stenosis: change of treatment plan based on repeat duplex ultrasonography. Am J Surg. 2012;203(2):121-6. [pmid: 21784407].
50 Gronholdt ML, Nordestgaard BG, Schroeder TV, et al. Ultrasonic echolucent carotid plaques predict future strokes. Circulation. 2001;104(1):68-73. [pmid: 11435340].
51 Groschel K, Ernemann U, Riecker A, et al. Incidence and risk factors for medical complications after carotid artery stenting. J Vasc Surg. 2005;42(6):1101-6. [pmid: 16376198].
52 Halliday A, Bulbulia R, Gray W, et al. Status update and interim results from the asymptomatic carotid surgery trial-2 (ACST-2). Eur J Vasc Endovasc Surg. 2013;46(5):510-8. [pmid: 24051108].
53 Hamdan AD, Pomposelli FB Jr, Gibbons GW, et al. Renal insufficiency and altered postoperative risk in carotid endarterectomy. J Vasc Surg. 1999;29(6):1006-11. [pmid: 10359934].
54 Harthun NL, Stukenborg GJ. Atrial fibrillation is associated with increased risk of perioperative stroke and death from carotid endarterectomy. J Vasc Surg. 2010;51(2):330-6. [pmid: 19879714].
55 Hawkins BM, Kennedy KF, Giri J, et al. Pre-procedural risk quantification for carotid stenting using the CAS score: a report from the NCDR CARE Registry. J Am Coll Cardiol. 2012;60(17):1617-22. [pmid: 22999733].
56 Heyer EJ, Mergeche JL, Bruce SS, et al. Statins reduce neurologic injury in asymptomatic carotid endarterectomy patients. Stroke. 2013;44(4):1150-2. [pmid: 23404722].
57 Hobson IR, Krupski WC, Weiss DG, et al. Influence of aspirin in the management of asymptomatic carotid artery stenosis. J Vasc Surg. 1993;17(2):257-65. [pmid: 8433421].
58 Hobson RW 2nd, Howard VJ, Roubin GS, et al. Carotid artery stenting is associated with increased complications in octogenarians: 30-day stroke and death rates in the CREST lead-in phase. J Vasc Surg. 2004;40(6):1106-11. [pmid: 15622363].
59 Hoke M, Schillinger M, Dick P, et al. Polymorphism of the palladin gene and cardiovascular outcome in patients with atherosclerosis. Eur J Clin Invest. 2011;41(4):365-71. [pmid: 21054356].
60 Hoke M, Speidl W, Schillinger M, et al. Polymorphism of the complement 5 gene and cardiovascular outcome in patients with atherosclerosis. Eur J Clin Invest. 2012;42(9):921-6. [pmid: 22452399].
61 Iihara K, Murao K, Sakai N, et al. Outcome of carotid endarterectomy and stent insertion based on grading of carotid endarterectomy risk: a 7-year prospective study. J Neurosurg. 2006;105(4):546-54. [pmid: 17044557].
62 Jansen C, Sprengers AM, Moll FL, et al. Prediction of intracerebral haemorrhage after carotid endarterectomy by clinical criteria and intraoperative transcranial Doppler monitoring. Eur J Vasc Surg. 1994;8(3):303-8. [pmid: 7912206].
63 Jaroslav P, Christian R, Stefan O, et al. Evaluation of serum biomarkers for patients at increased risk of stroke. Int J Vasc Med. 2012;2012.
64 Joakimsen O, Bonaa KH, Mathiesen EB, et al. Prediction of mortality by ultrasound screening of a general population for carotid stenosis: the Tromso Study. Stroke. 2000;31(8):1871-6. [pmid: 10926949].
65 Kakkos SK, Griffin MB, Nicolaides AN, et al. The size of juxtaluminal hypoechoic area in ultrasound images of asymptomatic carotid plaques predicts the occurrence of stroke. J Vasc Surg. 2013;57(3):609-18. [pmid: 23337294].
66 Kasper GC, Lohr JM, Welling RE. Clinical benefit of carotid endarterectomy based on duplex ultrasonography. Vasc Endovascular Surg. 2003;37(5):323-7. [pmid: 14528377].
67 Kastrup A, Groschel K, Schulz JB, et al. Clinical predictors of transient ischemic attack, stroke, or death within 30 days of carotid angioplasty and stenting. Stroke. 2005;36(4):787-91. [pmid: 15705938].
68 Kawahito S, Kitahata H, Tanaka K, et al. Risk factors for perioperative myocardial ischemia in carotid artery endarterectomy. J Cardiothorac Vasc Anesth. 2004;18(3):288-92. [pmid: 15232807].
69 King A, Serena J, Bornstein NM, et al. Does impaired cerebrovascular reactivity predict stroke risk in asymptomatic carotid stenosis? A prospective substudy of the asymptomatic carotid emboli study. Stroke. 2011;42(6):1550-5. [pmid: 21527764].
70 King A, Shipley M, Markus H. Optimizing protocols for risk prediction in asymptomatic carotid stenosis using embolic signal detection: the Asymptomatic Carotid Emboli Study. Stroke. 2011;42(10):2819-24. [pmid: 21852607].
71 Kitamura A, Iso H, Imano H, et al. Carotid intima-media thickness and plaque characteristics as a risk factor for stroke in Japanese elderly men. Stroke. 2004;35(12):2788-94. [pmid: 15528460].
72 Krapf H, Nagele T, Kastrup A, et al. Risk factors for periprocedural complications in carotid artery stenting without filter protection: a serial diffusion-weighted MRI study. J Neurol. 2006;253(3):364-71. [pmid: 16189645].
73 Lacroix P, Aboyans V, Criqui MH, et al. Type-2 diabetes and carotid stenosis: a proposal for a screening strategy in asymptomatic patients. Vasc Med. 2006;11(2):93-9. [pmid: 16886839].
74 Lam TD, Lammers S, Munoz C, et al. Diabetes, intracranial stenosis and microemboli in asymptomatic carotid stenosis. Can J Neurol Sci. 2013;40(2):177-81. [pmid: 23419564].
75 Macchi C, Catini C, Giannelli F. The original caliber of the carotid artery as a possible risk factor for complications of atherosclerosis. Ital J Anat Embryol. 1993;98(4):259-68. [pmid: 8018017].
76 Mannami T, Baba S, Ogata J. Strong and significant relationships between aggregation of major coronary risk factors and the acceleration of carotid atherosclerosis in the general population of a Japanese City: the Suita Study. Arch Intern Med. 2000;160(15):2297-303. [pmid: 10927726].
77 Mansour MA, Littooy FN, Watson WC, et al. Outcome of moderate carotid artery stenosis in patients who are asymptomatic. J Vasc Surg. 1999;29(2):217-25. [pmid: 9950980].
78 Marek J, Mills JL, Harvich J, et al. Utility of routine carotid duplex screening in patients who have claudication. J Vasc Surg. 1996;24(4):572-7. [pmid: 8911405].
79 Markus HS, King A, Shipley M, et al. Asymptomatic embolisation for prediction of stroke in the Asymptomatic Carotid Emboli Study (ACES): a prospective observational study. Lancet Neurol. 2010;9(7):663-71. [pmid: 20554250].
80 Matsumura JS, Gray W, Chaturvedi S, et al. Results of carotid artery stenting with distal embolic protection with improved systems: Protected Carotid Artery Stenting in Patients at High Risk for Carotid Endarterectomy (PROTECT) trial. J Vasc Surg. 2012;55(4):968-76. [pmid: 22236885].
81 McCollum PT, da Silva A, Ridler BD, et al. Carotid endarterectomy in the U.K. and Ireland: audit of 30-day outcome. The Audit Committee for the Vascular Surgical Society. Eur J Vasc Endovasc Surg. 1997;14(5):386-91. [pmid: 9413380].
82 McCrory DC, Goldstein LB, Samsa GP, et al. Predicting complications of carotid endarterectomy. Stroke. 1993;24(9):1285-91. [pmid: 8362419].
83 McDonald RJ, Cloft HJ, Kallmes DF. Intracranial hemorrhage is much more common after carotid stenting than after endarterectomy: evidence from the National Inpatient Sample. Stroke. 2011;42(10):2782-7. [pmid: 21836092].
84 Micieli G, Cavallini A, Bosone D, et al. Carotid artery atherosclerosis and risk factors for stroke in a selected population of asymptomatic men. Funct Neurol. 1998;13(1):27-35. [pmid: 9584872].
85 Mineva PP, Manchev IC, Hadjiev DI. Prevalence and outcome of asymptomatic carotid stenosis: a population-based ultrasonographic study. Eur J Neurol. 2002;9(4):383-8. [pmid: 12099923].
86 Mohan IV, Thomas SD. Do patients with asymptomatic carotid stenoses still benefit from surgical intervention?. ANZ J Surg. 2011;81(4):211-3. [pmid: 21418460].
87 Molloy J, Markus HS. Asymptomatic embolization predicts stroke and TIA risk in patients with carotid artery stenosis. Stroke. 1999;30(7):1440-3. [pmid: 10390320].
88 Momjian-Mayor I, Kuzmanovic I, Momjian S, et al. Accuracy of a novel risk index combining degree of stenosis of the carotid artery and plaque surface echogenicity. Stroke. 2012;43(5):1260-5. [pmid: 22403049].
89 Moneta GL, Taylor DC, Zierler RE, et al. Asymptomatic high-grade internal carotid artery stenosis: is stratification according to risk factors or duplex spectral analysis possible?. J Vasc Surg. 1989;10(5):475-82. [pmid: 2681840].
90 Mono ML, Karameshev A, Slotboom J, et al. Plaque characteristics of asymptomatic carotid stenosis and risk of stroke. Cerebrovasc Dis. 2012;34(5-6):343-50. [pmid: 23154753].
91 Morales MM, Anacleto A, Buchdid MA, et al. Morphological and hemodynamic patterns of carotid stenosis treated by endarterectomy with patch closure versus stenting: a duplex ultrasound study. Clinics (Sao Paulo). 2010;65(12):1315-23. [pmid: 21340221].
92 Mozes G, Sullivan TM, Torres-Russotto DR, et al. Carotid endarterectomy in SAPPHIRE-eligible high-risk patients: implications for selecting patients for carotid angioplasty and stenting. J Vasc Surg. 2004;39(5):958-65. [pmid: 15111844].
93 Mullenix PS, Martin MJ, Steele SR, et al. Rapid high-volume population screening for three major risk factors of future stroke: phase I results. Vasc Endovasc Surg. 2006;40(3):177-87.
94 Muller M, Reiche W, Langenscheidt P, et al. Ischemia after carotid endarterectomy: comparison between transcranial Doppler sonography and diffusion-weighted MR imaging. AJNR Am J Neuroradiol. 2000;21(1):47-54. [pmid: 10669224].
95 Nicolaides AN, Kakkos SK, Kyriacou E, et al. Asymptomatic internal carotid artery stenosis and cerebrovascular risk stratification. J Vasc Surg. 2010;52(6):1486-96. [pmid: 21146746].
96 Nolan BW, De Martino RR, Goodney PP, et al. Comparison of carotid endarterectomy and stenting in real world practice using a regional quality improvement registry. J Vasc Surg. 2012;56(4):990-6. [pmid: 22579135].
97 Papalambros E, Georgopoulos S, Sigala F, et al. Changes in circulating levels of vascular endothelial growth factor and vascular endothelial growth factor receptor-2 after carotid endarterectomy. Int J Mol Med. 2004;14(1):133-6. [pmid: 15202028].
98 Park BD, Divinagracia T, Madej O, et al. Predictors of clinically significant postprocedural hypotension after carotid endarterectomy and carotid angioplasty with stenting. J Vasc Surg. 2009;50(3):526-33. [pmid: 19700091].
99 Persson J, Folkersen L, Ekstrand J, et al. High plasma adiponectin concentration is associated with all-cause mortality in patients with carotid atherosclerosis. Atherosclerosis. 2012;225(2):491-6. [pmid: 23092825].
100 Pistolese GR, Ippoliti A, Appolloni A, et al. Cerebral haemodynamics during carotid cross-clamping. Eur J Vasc Surg. 1993;7(Suppl A):33-8. [pmid: 8458444].
101 Pitoulias GA, Tachtsi MD, Tsiaousis PZ, et al. Hyperhomocysteinemia and hypercoagulable state in carotid plaque evolution. Novel risk factors or coincidental risk predictors?. Int Angiol. 2007;26(3):270-8. [pmid: 17622211].
102 Prati P, Tosetto A, Casaroli M, et al. Carotid plaque morphology improves stroke risk prediction: usefulness of a new ultrasonographic score. Cerebrovasc Dis. 2011;31(3):300-4. [pmid: 21212660].
103 Ranke C, Creutzig A, Becker H, et al. Standardization of carotid ultrasound: a hemodynamic method to normalize for interindividual and interequipment variability. Stroke. 1999;30(2):402-6. [pmid: 9933279].
104 Reed AB, Gaccione P, Belkin M, et al. Preoperative risk factors for carotid endarterectomy: defining the patient at high risk. J Vasc Surg. 2003;37(6):1191-9. [pmid: 12764264].
105 Reinhard M, Gerds TA, Grabiak D, et al. Cerebral dysautoregulation and the risk of ischemic events in occlusive carotid artery disease. J Neurol. 2008;255(8):1182-9. [pmid: 18575926].
106 Reiter M, Bucek RA, Effenberger I, et al. Plaque echolucency is not associated with the risk of stroke in carotid stenting. Stroke. 2006;37(9):2378-80. [pmid: 16888264].
107 Rockman CB, Jacobowitz GR, Gagne PJ, et al. Focused screening for occult carotid artery disease: patients with known heart disease are at high risk. J Vasc Surg. 2004;39(1):44-51. [pmid: 14718811].
108 Roh HG, Byun HS, Ryoo JW, et al. Prospective analysis of cerebral infarction after carotid endarterectomy and carotid artery stent placement by using diffusion-weighted imaging. AJNR Am J Neuroradiol. 2005;26(2):376-84. [pmid: 15709140].
109 Roh YN, Woo SY, Kim N, et al. Prevalence of asymptomatic carotid stenosis in Korea based on health screening population. J Korean Med Sci. 2011;26(9):1173-7. [pmid: 21935272].
110 Rosenthal DE. Carotid endarterectomy in the octogenarian: is it appropriate?. J Vasc Surg. 1986;3(5).
111 Rothwell PM, Slattery J, Warlow CP. Clinical and angiographic predictors of stroke and death from carotid endarterectomy: systematic review. BMJ. 1997;315(7122):1571-7. [pmid: 9437274].
112 Sahlein DH, Heyer EJ, Rampersad A, et al. Failure of intraoperative jugular bulb S-100B and neuron-specific enolase sampling to predict cognitive injury after carotid endarterectomy. Neurosurgery. 2003;53(6):1243-9. [pmid: 14633290].
113 Samra SK, Dy EA, Welch K, et al. Evaluation of a cerebral oximeter as a monitor of cerebral ischemia during carotid endarterectomy. Anesthesiology. 2000;93(4):964-70. [pmid: 11020747].
114 Schlager O, Exner M, Mlekusch W, et al. C-reactive protein predicts future cardiovascular events in patients with carotid stenosis. Stroke. 2007;38(4):1263-8. [pmid: 17322087].
115 Schmidt P, Sliwka U, Simon SG, et al. High-grade stenosis of the internal carotid artery assessed by color and power Doppler imaging. J Clin Ultrasound. 1998;26(2):85-9. [pmid: 9460636].
116 Sherif C, Dick P, Sabeti S, et al. Neurological outcome of conservative versus endovascular treatment of patients with asymptomatic high-grade carotid artery stenosis: a propensity score-adjusted analysis. J Endovasc Ther. 2005;12(2):145-55. [pmid: 15823061].
117 Silvestrini M, Altamura C, Cerqua R, et al. Ultrasonographic markers of vascular risk in patients with asymptomatic carotid stenosis. J Cereb Blood Flow Metab. 2013;33(4):619-24. [pmid: 23361391].
118 Skjelland M, Krohg-Sorensen K, Tennoe B, et al. Cerebral microemboli and brain injury during carotid artery endarterectomy and stenting. Stroke. 2009;40(1):230-4. [pmid: 18927460].
119 Spence JD, Tamayo A, Lownie SP, et al. Absence of microemboli on transcranial Doppler identifies low-risk patients with asymptomatic carotid stenosis. Stroke. 2005;36(11):2373-8. [pmid: 16224084].
120 Stoner MC, Abbott WM, Wong DR, et al. Defining the high-risk patient for carotid endarterectomy: an analysis of the prospective National Surgical Quality Improvement Program database. J Vasc Surg. 2006;43(2):285-95. [pmid: 16476603].
121 Sutton-Tyrrell K, Alcorn HG, Wolfson SK Jr, et al. Predictors of carotid stenosis in older adults with and without isolated systolic hypertension. Stroke. 1993;24(3):355-61. [pmid: 8446969].
122 Takaya N, Yuan C, Chu B, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI—initial results. Stroke. 2006;37(3):818-23. [pmid: 16469957].
123 Topakian R, King A, Kwon SU, et al. Ultrasonic plaque echolucency and emboli signals predict stroke in asymptomatic carotid stenosis. Neurology. 2011;77(8):751-8. [pmid: 21849657].
124 van Lammeren GW, Moll FL, Blankestijn PJ, et al. Decreased kidney function: an unrecognized and often untreated risk factor for secondary cardiovascular events after carotid surgery. Stroke. 2011;42(2):307-12. [pmid: 21183753].
125 Willeit J, Kiechl S, Santer P, et al. Lipoprotein(a) and asymptomatic carotid artery disease. Evidence of a prominent role in the evolution of advanced carotid plaques: the Bruneck Study. Stroke. 1995;26(9):1582-7. [pmid: 7660402].
126 Wolf O, Heider P, Heinz M, et al. Microembolic signals detected by transcranial Doppler sonography during carotid endarterectomy and correlation with serial diffusion-weighted imaging. Stroke. 2004;35(11):e373-5. [pmid: 15388901].
127 Yamada K, Yoshimura S, Kawasaki M, et al. Prediction of silent ischemic lesions after carotid artery stenting using virtual histology intravascular ultrasound. Cerebrovasc Dis. 2011;32(2):106-13. [pmid: 21709408].
128 Yavas S, Mavioglu L, Kocabeyoglu S, et al. Is female gender really a risk factor for carotid endarterectomy?. Ann Vasc Surg. 2010;24(6):775-85. [pmid: 20471213].
129 Yuo TH, Goodney PP, Powell RJ, et al. “Medical high risk” designation is not associated with survival after carotid artery stenting. J Vasc Surg. 2008;47(2):356-62. [pmid: 18155875].
130 Zahn RE. Carotid artery stenting in octogenarians: result from the ALKK Carotid Artery Stent (CAS) Registry. Eur Heart J. 2007;28.