# Detailed Methods

Search Strategy

### Initial Searches

1/14/13 PubMed

Search | Query | Items found
#1 | Search (“Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis”) | 13181
#2 | Search asymptomatic | 100045
#3 | Search (#1 and #2) | 2650
#4 | Search “Mass Screening”[Mesh] | 92506
#5 | Search (#3 and #4) | 52
#6 | Search “Carotid Stenosis/ultrasonography”[Mesh] | 2304
#7 | Search “Ultrasonography”[Mesh] | 230227
#8 | Search (#3 and #7) | 590
#9 | Search “Endarterectomy, Carotid”[Mesh] | 6297
#10 | Search (#3 and #9) | 1139
#11 | Search “Angioplasty”[Mesh] | 51935
#12 | Search (#3 and #11) | 451
#13 | Search “Magnetic Resonance Angiography”[Mesh] | 15076
#14 | Search (#3 and #13) | 86
#15 | Search (“Angioplasty, Balloon”[Mesh] OR “balloon dilation”) | 47673
#16 | Search (#3 and #15) | 228
#17 | Search “Stents”[Mesh] | 47106
#18 | Search (#3 and #17) | 602
#19 | Search (“CT angiography”[tiab] OR “computed tomographic angiography”[tiab]) | 6410
#20 | Search (#3 and #19) | 32
#21 | Search “Carotid Stenosis/radiography”[Mesh] | 1613
#22 | Search (#3 and #21) | 236
#23 | Search (#5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22) | 3798
#24 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 615495
#25 | Search (#23 and #24) | 448
#26 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 101498
#27 | Search (#23 and #26) | 68
#28 | Search (#25 or #27) | 498
#29 | Search (“stroke”[MeSH Terms] OR “stroke”[All Fields] OR “brain infarction”[All Fields] OR “cerebrovascular disorder”[All Fields] OR “cerebrovascular disease”[All Fields] OR “CVA”[All Fields] OR “cerebral infarction”[All Fields] OR “ischemic stroke”[All Fields] OR ((“stroke”[MeSH Terms] OR “stroke”[All Fields]) AND (“ischemia”[MeSH Terms] OR “ischemia”[All Fields] OR “ischemic”[All Fields])) OR “cerebrovascular accident”[All Fields]) | 201437
#30 | Search (“risk”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR “risk adjustment”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR (“risk”[All Fields] AND “assessment”[All Fields]) OR “risk assessment”[All Fields] OR (“assessment”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields]) OR (“assessments”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields])) | 799562
#31 | Search (#3 and #29 and #30) | 818
#32 | Search (#31 and #24) | 132
#33 | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “comparative study”[pt] OR “Epidemiologic Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “observational study” OR “observational studies” OR “cohort”[tw] OR “case control”[tw]) | 2911595
#34 | Search (#31 and #33) | 484
#35 | Search (#32 or #34) | 524
#36 | Search (#5 or #6 or #8 or #14 or #20 or #22) | 2774
#37 | Search (#36 and #26) | 29
#38 | Search (“Endarterectomy, Carotid/statistics and numerical data”[Mesh]) | 769
#39 | Search “Endarterectomy, Carotid/adverse effects”[Mesh] | 1573
#40 | Search (#23 or #38 or #39) | 5322
#41 | Search (harm OR harms OR adverse effect* OR adverse event* OR complication* OR death OR stroke OR “Myocardial Infarction”[Mesh] OR “myocardial infarction” OR (unnecessary AND “carotid endarterectomy”) OR “Kidney Failure, Chronic”[Mesh] OR “Renal Insufficiency”[Mesh] OR “Cranial Nerve Diseases”[Mesh] OR “Cranial Nerve Injuries”[Mesh] OR (neck AND hematoma*)) | 3944352
#42 | Search (#40 and #41) | 4080
#43 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1348329
#44 | Search (#25 or #27) Filters: Humans | 494
#45 | Search (#25 or #27) Filters: Humans; English | 458
#46 | Search (#25 or #27) Filters: Humans; English; Adult: 19+ years | 283
#47 | Search (#46 NOT #43) | 283
#48 | Search (#32 or #34) Filters: Humans | 524
#49 | Search (#32 or #34) Filters: Humans; English | 485
#50 | Search (#32 or #34) Filters: Humans; English; Adult: 19+ years | 414
#51 | Search (#50 NOT #43) | 413
#52 | Search (#36 and #26) Filters: Humans | 28
#53 | Search (#36 and #26) Filters: Humans; English | 26
#54 | Search (#36 and #26) Filters: Humans; English; Adult: 19+ years | 7
#55 | Search (#54 NOT #43) | 7
#56 | Search (#40 and #41) Filters: Humans | 4056
#57 | Search (#40 and #41) Filters: Humans; English | 3666
#58 | Search (#40 and #41) Filters: Humans; English; Adult: 19+ years | 2606
#59 | Search (#58 NOT #43) | 2548
#60 | Search (#47 or #51 or #55 or #59) | 2667

1/14/13 Cochrane Library

ID | Search | Hits
#1 | [mh “Carotid Stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 817
#2 | asymptomatic | 5592
#3 | #1 and #2 | 254
#4 | [mh “Mass Screening”] | 4250
#5 | #3 and #4 | 7
#6 | [mh “Carotid Stenosis”/US] | 109
#7 | [mh Ultrasonography] | 6706
#8 | #3 and #7 | 47
#9 | [mh “Endarterectomy, Carotid”] | 442
#10 | #3 and #9 | 121
#11 | [mh Angioplasty] | 3950
#12 | #3 and #11 | 36
#13 | [mh “Magnetic Resonance Angiography”] | 338
#14 | #3 and #13 | 4
#15 | [mh “Angioplasty, Balloon”] or “balloon dilation” | 4135
#16 | #3 and #15 | 19
#17 | [mh Stents] | 2939
#18 | #3 and #17 | 49
#19 | “CT angiography” or “computed tomographic angiography” | 242
#20 | #3 and #19 | 3
#21 | [mh “Carotid Stenosis”/RA] | 52
#22 | #3 and #21 | 11
#23 | #5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22 | 242
#24 | “Randomized Controlled Trial” or rct or “Single-Blind Method” or “Double-Blind Method” or “Random Allocation” or trial | 716586
#25 | #23 and #24 | 220
#26 | (review and systematic) or “systematic review” or ([mh “review literature as topic”] and systematic) or “meta-analysis” or [mh “meta-analysis as topic”] | 36928
#27 | #23 and #26 | 47
#28 | #25 or #27 | 226
#29 | [mh stroke] or stroke or “brain infarction” or “cerebrovascular disorder” or “cerebrovascular disease” or CVA or “cerebral infarction” or “ischemic stroke” or (stroke and (ischemia or ischemic)) or “cerebrovascular accident” | 28247
#30 | [mh risk] or [mh “risk assessment”] or [mh “risk adjustment”] or (risk and assessment) or “risk assessment” | 46693
#31 | #3 and #29 and #30 | 111
#32 | #31 and #24 | 99
#33 | “Case-Control Studies” or “Cohort Studies” or “comparative study” or “Epidemiologic Studies” or “Cross-Over Studies” or “Follow-Up Studies” or “observational study” or “observational studies” or “cohort” or “case control” | 200532
#34 | #31 and #33 | 57
#35 | #32 or #34 | 104
#36 | #5 or #6 or #8 or #14 or #20 or #22 | 141
#37 | #36 and #26 | 12
#38 | [mh “Endarterectomy, Carotid”/SN] | 15
#39 | [mh “Endarterectomy, Carotid”/AE] | 110
#40 | #23 or #38 or #39 | 322
#41 | harm or harms or adverse effect* or adverse event* or complication* or death or stroke or [mh “Myocardial Infarction”] or “myocardial infarction” or (unnecessary and “carotid endarterectomy”) or [mh “Kidney Failure, Chronic”] or [mh “Renal Insufficiency”] or [mh “Cranial Nerve Diseases”] or [mh “Cranial Nerve Injuries”] or (neck and hematoma*) | 229088
#42 | #40 and #41 | 295
#43 | comment:pt or editorial:pt or letter:pt or news:pt | 6335
#44 | #28 not #43 | 223
#45 | #35 not #43 | 104
#46 | #37 not #43 | 12
#47 | #42 not #43 | 293
#48 | #44 or #45 or #46 or #47 | 330

1/14/13 Embase

Search | Query | Items Found
#52 | #45 OR #47 OR #49 OR #51 AND [embase]/lim | 1,805
#51 | #50 NOT #43 AND [embase]/lim | 1,618
#50 | #42 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim | 1,652
#49 | #48 NOT #43 AND [embase]/lim | 45
#48 | #37 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim | 45
#47 | #46 NOT #43 AND [embase]/lim | 252
#46 | #35 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim | 254
#45 | #44 NOT #43 AND [embase]/lim | 430
#44 | #28 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim | 432
#43 | ‘editorial’/exp OR ‘letter’/exp AND [embase]/lim | 902,998
#42 | #40 AND #41 AND [embase]/lim | 3,297
#41 | Harm OR harms OR adverse AND effect* OR ‘adverse outcome’/exp OR ‘adverse event’ OR ‘adverse events’ OR complication* OR ‘death’/exp OR ‘stroke’/exp OR ‘heart infarction’/exp OR ‘myocardial infarction’/exp OR (unnecessary AND ‘carotid endarterectomy’/exp) OR ‘chronic kidney failure’/exp OR ‘kidney failure’/exp OR ‘cranial neuropathy’/exp OR ‘cranial nerve injury’/exp OR (‘neck’/exp AND hematoma*) AND [embase]/lim | 2,755,904
#40 | #23 OR #38 OR #39 AND [embase]/lim | 5,265
#39 | ‘carotid endarterectomy’/exp AND ‘adverse outcome’/exp AND [embase]/lim | 33
#38 | ‘carotid endarterectomy’/exp AND ‘health statistics’/exp AND [embase]/lim | 2
#37 | #36 AND #26 AND [embase]/lim | 420
#36 | #5 OR OR #6 OR #8 OR #14 OR #20 OR #22 AND [embase]/lim | 3,859
#35 | #32 OR #34 AND [embase]/lim | 650
#34 | #31 AND #33 AND [embase]/lim | 433
#33 | ‘cohort analysis’/exp OR ‘comparative study’/exp OR ‘epidemiological study’ OR ‘crossover procedure’/exp OR ‘follow up’/exp OR ‘case control study’/exp OR ‘observational study’/exp OR ‘observational studies’/exp OR cohort AND [embase]/lim | 1,315,793
#32 | #31 AND #24 AND [embase]/lim | 371
#31 | #3 AND #29 AND #30 AND [embase]/lim | 1,290
#30 | ‘risk’/exp OR ‘risk assessment’/exp OR ‘risk adjustment’/exp OR (‘risk’/exp AND assessment) OR (assessment AND benefit AND ‘risk’/exp) OR (assessments AND benefit AND ‘risk’/exp) AND [embase]/lim | 1,043,208
#29 | ‘stroke’/exp OR ‘brain infarction’/exp OR ‘cerebrovascular disease’/exp OR ‘cerebral infarction’/exp OR ‘brain ischemia’/exp OR ischemic OR ‘ischemia’/exp OR ‘cerebrovascular accident’/exp OR ‘cva’/exp AND [embase]/lim | 742,015
#28 | #25 OR #27 AND [embase]/lim | 1,385
#27 | #23 AND #26 AND [embase]/lim | 671
#26 | ‘review’/exp OR (systematic AND ‘review’/exp) OR ‘systematic review’/exp OR (‘literature’/exp AND ‘review’/exp AND systematic) OR ‘meta analysis (topic)’/exp OR ‘meta analysis’/exp AND [embase]/lim | 1,328,033
#25 | #23 AND #24 AND [embase]/lim | 987
#24 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR trial AND [embase]/lim | 1,012,147
#23 | #5 OR #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 OR #22 AND [embase]/lim | 5,239
#22 | #3 AND #21 AND [embase]/lim | 3
#21 | ‘carotid artery obstruction’/exp/dm_rt AND [embase]/lim | 11
#20 | #3 AND #19 AND [embase]/lim | 94
#19 | ‘computed tomographic angiography’/exp AND [embase]/lim | 17,301
#18 | #3 AND #17 AND [embase]/lim | 626
#17 | ‘stent’/exp AND [embase]/lim | 76,186
#16 | #3 AND #15 AND [embase]/lim | 74
#15 | ‘carotid angioplasty’/exp OR ‘balloon dilatation’/exp AND [embase]/lim | 8,331
#14 | #3 AND #13 AND [embase]/lim | 159
#13 | ‘magnetic resonance angiography’/exp AND [embase]/lim | 18,209
#12 | #3 AND #11 AND [embase]/lim | 707
#11 | ‘angioplasty’/exp AND [embase]/lim | 50,229
#10 | #3 AND #9 AND [embase]/lim | 1,414
#9 | ‘carotid endarterectomy’/exp AND [embase]/lim | 10,608
#8 | #3 AND #7 | 727
#7 | ‘echography’/exp AND [embase]/lim | 376,374
#6 | ‘carotid artery obstruction’/exp AND ‘echography’/exp AND [embase]/lim | 3,724
#5 | #3 AND #4 AND [embase]/lim | 10
#4 | ‘mass screening’/exp AND [embase]/lim | 100,488
#3 | #1 AND #2 AND [embase]/lim | 2,998
#2 | asymptomatic AND [embase]/lim | 106,122
#1 | ‘carotid artery obstruction’/exp OR ‘carotid stenosis’/exp OR ‘carotid artery stenosis’/exp AND [embase]/lim | 19,804

### Additional searches (for drugs) for KQ 6 (PubMed and Cochrane Library)

4/11/13 PubMed

Search | Query | Items found
#19 | Search “Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis” | 13363
#20 | Search asymptomatic | 101659
#21 | Search (#19 and #20) | 2691
#22 | Search (“Aspirin”[Mesh] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Pharmacological Action] OR statins[tiab] OR “Platelet Aggregation Inhibitors”[Mesh] OR “Drug Therapy”[Mesh] OR “drug therapy”[subheading]) | 2173853
#23 | Search (#21 and #22) | 240
#29 | Search (“Chemicals and Drugs Category”[Mesh]) | 10950565
#30 | Search (#21 and #29) | 508
#31 | Search (#30 NOT #23) | 318
#32 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 625507
#33 | Search (#31 and #32) | 18
#34 | Search (#31 and #32) Filters: Humans | 18
#35 | Search (#31 and #32) Filters: Humans; English | 15
#36 | Search (#31 and #32) Filters: Humans; English; Adult: 19+ years | 13
#37 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) Filters: Humans; English; Adult: 19+ years | 19048
#38 | Search (#31 and #37) Filters: Humans; English; Adult: 19+ years | 0
#39 | Search (Chlorthalidone[mesh] AND #31) | 0
#40 | Search (Chlorthalidone[mesh] and #21) | 0
#42 | Search (Hydrochlorothiazide[mesh] AND #21) | 3
#43 | Search (#42 and (#32 or #37)) Filters: Humans; English; Adult: 19+ years | 3
#44 | Search (#43 NOT (#23 or #36)) Filters: Humans; English; Adult: 19+ years | 0
#45 | Search (“Lisinopril”[Mesh] AND #21) Filters: Humans; English; Adult: 19+ years | 0
#46 | Search (“Atenolol”[Mesh] AND #21) Filters: Humans; English; Adult: 19+ years | 0
#47 | Search (Metoprolol[Mesh] AND #21) Filters: Humans; English; Adult: 19+ years | 0

4/11/13 Cochrane Library (3 results; 1 Cochrane review and 2 trials. All 3 were retrieved in previous searches)

ID | Search | Hits
#1 | [mh “Carotid Stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 827
#2 | asymptomatic | 5655
#3 | #1 and #2 | 260
#4 | [mh Aspirin] or [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] or (statins:ti or statins:ab) or [mh “Platelet Aggregation Inhibitors”] or [mh “Drug Therapy”] or [mh /DT] | 200682
#5 | #3 and #4 | 35
#6 | [mh “Pharmacologic Actions”] | 156873
#7 | #3 and #6 | 23
#8 | #7 not #5 | 3

### CAS Gray Literature Searches

A. WHO ICTRP (International Clinical Trials Registry Platform) search 2-12-13
  1. 16 results for Title search: “carotid stenosis” OR “carotid artery stenosis”
  2. 32 results for Condition search: “carotid stenosis” OR “carotid artery stenosis”
B. ClinicalTrials.gov search 2-12-13 (94 trials) ( ( “carotid stenosis” OR “carotid artery stenosis” AND asymptomatic ) AND ( “Mass Screening” OR screening OR Ultrasonography OR “carotid endarterectomy” OR Angioplasty OR “Magnetic Resonance Angiography” OR “balloon angioplasty” OR “balloon dilation” OR stent* OR “CT angiography” OR “computed tomographic angiography” OR radiography ) ) [ALL-FIELDS]
C. We said we would search Cochrane Stroke Group Trials registry, but I could not figure out how to search for trials specifically within that group, so I repeated a search in Cochrane Central Register of Controlled Trials (CENTRAL) limited to trials and groups, but did not limit to study types except to remove editorials, letter, comments, news; and found 170 results. I checked this against our original Cochrane search and it should add 120 new citations and discard 50 duplicates. Here is the search:

2/11/13 Cochrane Trials Search

ID | Search | Hits
#1 | [mh “carotid stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 822
#2 | asymptomatic | 5618
#3 | #1 and #2 | 258
#4 | [mh “mass screening”] | 4337
#5 | #3 and #4 | 7
#6 | [mh “carotid stenosis”/US] | 109
#7 | [mh ultrasonography] | 6749
#8 | #3 and #7 | 47
#9 | [mh “endarterectomy, carotid”] | 446
#10 | #3 and #9 | 124
#11 | [mh angioplasty] | 3972
#12 | #3 and #11 | 38
#13 | [mh “Magnetic Resonance Angiography”] | 340
#14 | #3 and #13 | 4
#15 | [mh “angioplasty, balloon”] or “balloon dilation” | 4150
#16 | #3 and #15 | 19
#17 | [mh stents] | 2971
#18 | #3 and #17 | 51
#19 | “CT angiography”:ti or “CT angiography”:ab or “computed tomographic angiography”:ti or “computed tomographic angiography”:ab | 186
#20 | #3 and #19 | 2
#21 | [mh “carotid stenosis”/RA] | 52
#22 | #3 and #21 | 11
#23 | #5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22 | 244
#24 | comment:pt or editoral:pt or letter:pt or news:pt | 6182
#25 | #23 not #24 in Trials and Cochrane Groups | 170

### Bridge Searches

9/27/13 and 10/3/13

Search | Query | Items found
#1 | Search (“Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis”) | 13743
#2 | Search asymptomatic | 104694
#3 | Search (#1 and #2) | 2770
#4 | Search “Aspirin”[Mesh] | 36926
#5 | Search (#3 and #4) | 73
#6 | Search “Hydroxymethylglutaryl-CoA Reductase Inhibitors”[Mesh] | 18957
#7 | Search “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Pharmacological Action] | 27130
#8 | Search (#6 or #7) | 27130
#9 | Search (#3 and #8) | 39
#10 | Search (#3 AND statins[tiab]) | 39
#11 | Search (#9 or #10) | 63
#12 | Search “Platelet Aggregation Inhibitors”[Mesh] | 25236
#13 | Search (#3 and #12) | 79
#14 | Search “Drug Therapy”[Mesh] | 1006539
#15 | Search “drug therapy”[subheading] | 1621742
#16 | Search (#14 or #15) | 2176937
#17 | Search (#3 and #16) | 159
#18 | Search (#5 or #11 or #13 or #17) | 251
#19 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 645662
#20 | Search (#18 and #19) | 69
#21 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 114200
#22 | Search (#18 and #21) | 13
#23 | Search (#20 or #22) | 79
#24 | Search (#20 or #22) Filters: Humans | 76
#25 | Search (#20 or #22) Filters: Humans; English | 72
#26 | Search (#20 or #22) Filters: Humans; English; Adult: 19+ years | 44
#27 | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] AND #18) | 0
#28 | Search (#20 or #22) Filters: Publication date from 2013/01/01 to 2013/12/31; Humans; English; Adult: 19+ years | 2

03/10/13 Cochrane Update Search for Statins (4 New)

ID | Search | Hits
#1 | [mh “Carotid Stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 853
#2 | asymptomatic | 5775
#3 | #1 and #2 | 268
#4 | [mh Aspirin] | 657
#5 | #3 and #4 | 4
#6 | [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] | 2444
#7 | #3 and #6 | 2
#8 | #3 and (statins:ti or statins:ab) | 2
#9 | [mh “Platelet Aggregation Inhibitors”] | 2762
#10 | #3 and #9 | 12
#11 | [mh “Drug Therapy”] or [mh /DT] | 202679
#12 | #3 and #11 | 32
#13 | #5 or #7 or #8 or #10 or #12 from 2012 to 2013 | 4

9/27/13 PubMed (63 results) and Retractions (3) (KQs 1-5, 7, and 8 search [separate/additional searches were conducted for KQ 6])

Search | Query | Items found
#1 | Search “Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis” | 13732
#2 | Search asymptomatic | 104580
#3 | Search (#1 and #2) | 2768
#4 | Search “Mass Screening”[Mesh] | 95673
#5 | Search (#3 and #4) | 53
#6 | Search “Carotid Stenosis/ultrasonography”[Mesh] | 2371
#7 | Search “Ultrasonography”[Mesh] | 238537
#8 | Search (#3 and #7) | 619
#9 | Search “Endarterectomy, Carotid”[Mesh] | 6520
#10 | Search (#3 and #9) | 1188
#11 | Search “Angioplasty”[Mesh] | 53078
#12 | Search (#3 and #11) | 469
#13 | Search “Magnetic Resonance Angiography”[Mesh] | 15908
#14 | Search (#3 and #13) | 90
#15 | Search (“Angioplasty, Balloon”[Mesh] OR “balloon dilation”) | 48723
#16 | Search (#3 and #15) | 235
#17 | Search “Stents”[Mesh] | 49701
#18 | Search (#3 and #17) | 640
#19 | Search (“CT angiography”[tiab] OR “computed tomographic angiography”[tiab]) | 7038
#20 | Search (#3 and #19) | 36
#21 | Search “Carotid Stenosis/radiography”[Mesh] | 1664
#22 | Search (#3 and #21) | 246
#23 | Search (#5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22) | 3937
#24 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 645006
#25 | Search (#23 and #24) | 462
#26 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 113879
#27 | Search (#23 and #26) | 75
#28 | Search (#25 or #27) | 518
#29 | Search (“stroke”[MeSH Terms] OR “stroke”[All Fields] OR “brain infarction”[All Fields] OR “cerebrovascular disorder”[All Fields] OR “cerebrovascular disease”[All Fields] OR “CVA”[All Fields] OR “cerebral infarction”[All Fields] OR “ischemic stroke”[All Fields] OR ((“stroke”[MeSH Terms] OR “stroke”[All Fields]) AND (“ischemia”[MeSH Terms] OR “ischemia”[All Fields] OR “ischemic”[All Fields])) OR “cerebrovascular accident”[All Fields]) | 213772
#30 | Search (“risk”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR “risk adjustment”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR (“risk”[All Fields] AND “assessment”[All Fields]) OR “risk assessment”[All Fields] OR (“assessment”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields]) OR (“assessments”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields])) | 843578
#31 | Search (#3 and #29 and #30) | 861
#32 | Search (#31 and #24) | 138
#33 | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “comparative study”[pt] OR “Epidemiologic Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “observational study” OR “observational studies” OR “cohort”[tw] OR “case control”[tw]) | 3019090
#34 | Search (#31 and #33) | 508
#35 | Search (#32 or #34) | 551
#36 | Search (#5 or #6 or #8 or #14 or #20 or #22) | 2868
#37 | Search (#36 and #26) | 29
#38 | Search (“Endarterectomy, Carotid/statistics and numerical data”[Mesh]) | 813
#39 | Search “Endarterectomy, Carotid/adverse effects”[Mesh] | 1666
#40 | Search (#23 or #38 or #39) | 5541
#41 | Search (harm OR harms OR adverse effect* OR adverse event* OR complication* OR death OR stroke OR “Myocardial Infarction”[Mesh] OR “myocardial infarction” OR (unnecessary AND “carotid endarterectomy”) OR “Kidney Failure, Chronic”[Mesh] OR “Renal Insufficiency”[Mesh] OR “Cranial Nerve Diseases”[Mesh] OR “Cranial Nerve Injuries”[Mesh] OR (neck AND hematoma*)) | 4084165
#42 | Search (#40 and #41) | 4269
#43 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1407811
#44 | Search (#25 or #27) Filters: Humans | 515
#45 | Search (#25 or #27) Filters: Humans; English | 478
#46 | Search (#25 or #27) Filters: Humans; English; Adult: 19+ years | 293
#47 | Search (#46 NOT #43) | 293
#48 | Search (#32 or #34) Filters: Humans | 551
#49 | Search (#32 or #34) Filters: Humans; English | 512
#50 | Search (#32 or #34) Filters: Humans; English; Adult: 19+ years | 439
#51 | Search (#50 NOT #43) | 438
#52 | Search (#36 and #26) Filters: Humans | 29
#53 | Search (#36 and #26) Filters: Humans; English | 27
#54 | Search (#36 and #26) Filters: Humans; English; Adult: 19+ years | 7
#55 | Search (#54 NOT #43) | 7
#56 | Search (#40 and #41) Filters: Humans | 4245
#57 | Search (#40 and #41) Filters: Humans; English | 3832
#58 | Search (#40 and #41) Filters: Humans; English; Adult: 19+ years | 2732
#59 | Search (#58 NOT #43) | 2673
#60 | Search (#47 or #51 or #55 or #59) | 2795
#61 | Search (#60 AND (2012/12/14:2013/09/27[edat])) | 63
#62 | Search (#21 or #31 or #42) | 5732
#63 | Search (#62 AND (“retraction”[All Fields] OR “Retracted Publication”[pt])) | 3

KQ 6 Search Update for Additional Drugs (1 new RCT and 0 retractions. The 1 new RCT was a duplicate with the search above and was discarded)

Search | Query | Items found
#1 | Search (“Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis”) | 13732
#2 | Search asymptomatic | 104580
#3 | Search (#1 and #2) | 2768
#4 | Search (“Aspirin”[Mesh] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Pharmacological Action] OR statins[tiab] OR “Platelet Aggregation Inhibitors”[Mesh] OR “Drug Therapy”[Mesh] OR “drug therapy”[subheading]) | 2222027
#5 | Search (#3 and #4) | 251
#6 | Search (“Chemicals and Drugs Category”[Mesh]) | 11152919
#7 | Search (#3 and #6) | 533
#8 | Search (#7 NOT #5) | 332
#9 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 645006
#10 | Search (#8 and #9) | 19
#11 | Search (#8 and #9) Filters: Humans | 19
#12 | Search (#8 and #9) Filters: Humans; English | 16
#13 | Search (#8 and #9) Filters: Humans; English; Adult: 19+ years | 14
#14 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields])) Filters: Humans; English; Adult: 19+ years | 20306
#15 | Search (#8 and #14) Filters: Humans; English; Adult: 19+ years | 0
#16 | Search (Chlorthalidone[mesh] AND #8) | 0
#17 | Search (Chlorthalidone[mesh] AND #3) | 0
#18 | Search (Hydrochlorothiazide[mesh] AND #3) | 3
#19 | Search (#18 AND (#9 or #14)) | 3
#20 | Search (#18 AND (#9 or #14)) Filters: Humans | 3
#21 | Search (#18 AND (#9 or #14)) Filters: Humans; English | 3
#22 | Search (#18 AND (#9 or #14)) Filters: Humans; English; Adult: 19+ years | 3
#23 | Search (#22 NOT (#5 or #13)) Filters: Humans; English; Adult: 19+ years | 0
#24 | Search (“Lisinopril”[Mesh] AND #3) Filters: Humans; English; Adult: 19+ years | 0
#25 | Search (“Atenolol”[Mesh] AND #3) Filters: Humans; English; Adult: 19+ years | 0
#26 | Search (“Metoprolol”[Mesh] AND #3) Filters: Humans; English; Adult: 19+ years | 0
#27 | Search (#13 AND (2013/03/11:2013/09/27[edat])) Filters: Humans; English; Adult: 19+ years | 1

9/27/2013 Cochrane Library Update Search

ID | Search | Hits
#1 | [mh “Carotid Stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 853
#2 | asymptomatic | 5772
#3 | #1 and #2 | 268
#4 | [mh “Mass Screening”] | 4548
#5 | #3 and #4 | 7
#6 | [mh “Carotid Stenosis”/US] | 112
#7 | [mh Ultrasonography] | 6996
#8 | #3 and #7 | 48
#9 | [mh “Endarterectomy, Carotid”] | 461
#10 | #3 and #9 | 129
#11 | [mh Angioplasty] | 4239
#12 | #3 and #11 | 38
#13 | [mh “Magnetic Resonance Angiography”] | 350
#14 | #3 and #13 | 5
#15 | [mh “Angioplasty, Balloon”] or “balloon dilation” | 4026
#16 | #3 and #15 | 19
#17 | [mh Stents] | 3110
#18 | #3 and #17 | 54
#19 | “CT angiography” or “computed tomographic angiography” | 275
#20 | #3 and #19 | 3
#21 | [mh “Carotid Stenosis”/RA] | 53
#22 | #3 and #21 | 11
#23 | [mh Aspirin] or [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] or (statins:ti or statins:ab) or [mh “Platelet Aggregation Inhibitors”] or [mh “Drug Therapy”] or [mh /DT] | 204690
#24 | #3 and #23 | 38
#25 | [mh “Pharmacologic Actions”] | 160591
#26 | #3 and #25 | 25
#27 | #26 not #24 | 3
#28 | #5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22 or #27 | 255
#29 | “Randomized Controlled Trial” or rct or “Single-Blind Method” or “Double-Blind Method” or “Random Allocation” or trial | 750415
#30 | #28 and #29 | 230
#31 | (review and systematic) or “systematic review” or ([mh “review literature as topic”] and systematic) or “meta-analysis” or [mh “meta-analysis as topic”] | 43560
#32 | #28 and #31 | 51
#33 | #30 or #32 | 236
#34 | [mh stroke] or stroke or “brain infarction” or “cerebrovascular disorder” or “cerebrovascular disease” or CVA or “cerebral infarction” or “ischemic stroke” or (stroke and (ischemia or ischemic)) or “cerebrovascular accident” | 29927
#35 | [mh risk] or [mh “risk assessment”] or [mh “risk adjustment”] or (risk and assessment) or “risk assessment” | 50215
#36 | #3 and #34 and #35 | 117
#37 | #36 and #29 | 104
#38 | “Case-Control Studies” or “Cohort Studies” or “comparative study” or “Epidemiologic Studies” or “Cross-Over Studies” or “Follow-Up Studies” or “observational study” or “observational studies” or “cohort” or “case control” | 206465
#39 | #36 and #38 | 61
#40 | #37 or #39 | 109
#41 | #5 or #6 or #8 or #14 or #20 or #22 | 146
#42 | #41 and #31 | 12
#43 | [mh “Endarterectomy, Carotid”/SN] | 16
#44 | [mh “Endarterectomy, Carotid”/AE] | 115
#45 | #28 or #43 or #44 | 339
#46 | harm or harms or adverse effect* or adverse event* or complication* or death or stroke or [mh “Myocardial Infarction”] or “myocardial infarction” or (unnecessary and “carotid endarterectomy”) or [mh “Kidney Failure, Chronic”] or [mh “Renal Insufficiency”] or [mh “Cranial Nerve Diseases”] or [mh “Cranial Nerve Injuries”] or (neck and hematoma*) | 237643
#47 | #45 and #46 | 310
#48 | comment:pt or editorial:pt or letter:pt or news:pt | 6431
#49 | #33 not #48 | 233
#50 | #40 not #48 | 109
#51 | #42 not #48 | 12
#52 | #47 not #48 | 308
#53 | #49 or #50 or #51 or #52 from 2012 to 2013 | 20

### 9/27/13 Gray Literature Updates

#### ClinicalTrials.gov yielded 6 results

(“Mass Screening” OR screening OR Ultrasonography OR “carotid endarterectomy” OR Angioplasty OR “Magnetic Resonance Angiography” OR “balloon angioplasty” OR “balloon dilation” OR stent* OR “CT angiography” OR “computed tomographic angiography” OR radiography) [ALL-FIELDS] AND ( ( “carotid stenosis” OR “carotid artery stenosis” AND asymptomatic ) AND ( “01/12/2013” : “09/27/2013” ) [FIRST-RECEIVED-DATE] ) [ALL-FIELDS]

Cochrane Trials Search (2 of the 3 results were trials and were saved, but both were duplicates with other update searches [the main Cochrane library update above])

ID | Search | Hits
#1 | [mh “Carotid Stenosis”] or “carotid stenosis” or “carotid artery stenosis” | 853
#2 | asymptomatic | 5772
#3 | #1 and #2 | 268
#4 | [mh “Mass Screening”] | 4548
#5 | #3 and #4 | 7
#6 | [mh “Carotid Stenosis”/US] | 112
#7 | [mh Ultrasonography] | 6996
#8 | #3 and #7 | 48
#9 | [mh “Endarterectomy, Carotid”] | 461
#10 | #3 and #9 | 129
#11 | [mh Angioplasty] | 4239
#12 | #3 and #11 | 38
#13 | [mh “Magnetic Resonance Angiography”] | 350
#14 | #3 and #13 | 5
#15 | [mh “Angioplasty, Balloon”] or “balloon dilation” | 4026
#16 | #3 and #15 | 19
#17 | [mh Stents] | 3110
#18 | #3 and #17 | 54
#19 | “CT angiography” or “computed tomographic angiography” | 275
#20 | #3 and #19 | 3
#21 | [mh “Carotid Stenosis”/RA] | 53
#22 | #3 and #21 | 11
#23 | #5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22 | 253
#24 | [mh Aspirin] or [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] or (statins:ti or statins:ab) or [mh “Platelet Aggregation Inhibitors”] or [mh “Drug Therapy”] or [mh /DT] | 204690
#25 | #3 and #24 | 38
#26 | [mh “Pharmacologic Actions”] | 160591
#27 | #3 and #26 | 25
#28 | #27 not #25 | 3
#29 | #23 or #28 | 255
#30 | comment:pt or editoral:pt or letter:pt or news:pt | 6273
#31 | #29 not #30 from 2013 to 2013 | 3

### 9/27/13 WHO ICTRP (International Clinical Trials Registry Platform) Search Update

1. 0 results for Title search: “carotid stenosis” OR “carotid artery stenosis” limited to trials with registry dates between 12/01/2013 - 27/09/2013
2. 0 results for Condition search: “carotid stenosis” OR “carotid artery stenosis” limited to trials with registry dates between 12/01/2013 - 27/09/2013

4/24/2014 Targeted MEDLINE Update Search

Search | Query | Items found
#1 | Search (“Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis”) | 14210
#2 | Search asymptomatic | 108605
#3 | Search (#1 and #2) | 2859
#4 | Search “Mass Screening”[Mesh] | 98103
#5 | Search (#3 and #4) | 56
#6 | Search “Carotid Stenosis/ultrasonography”[Mesh] | 2424
#7 | Search “Ultrasonography”[Mesh] | 244873
#8 | Search (#3 and #7) | 628
#9 | Search “Endarterectomy, Carotid”[Mesh] | 6674
#10 | Search (#3 and #9) | 1213
#11 | Search “Angioplasty”[Mesh] | 53821
#12 | Search (#3 and #11) | 476
#13 | Search “Magnetic Resonance Angiography”[Mesh] | 16545
#14 | Search (#3 and #13) | 94
#15 | Search (“Angioplasty, Balloon”[Mesh] OR “balloon dilation”) | 49374
#16 | Search (#3 and #15) | 236
#17 | Search “Stents”[Mesh] | 51808
#18 | Search (#3 and #17) | 651
#19 | Search (“CT angiography”[tiab] OR “computed tomographic angiography”[tiab]) | 7542
#20 | Search (#3 and #19) | 38
#21 | Search “Carotid Stenosis/radiography”[Mesh] | 1711
#22 | Search (#3 and #21) | 250
#23 | Search (#5 or #6 or #8 or #10 or #12 or #14 or #16 or #18 or #20 or #22) | 4028
#24 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 670734
#25 | Search (#23 and #24) | 471
#26 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 125426
#27 | Search (#23 and #26) | 77
#28 | Search (#25 or #27) | 529
#29 | Search (“stroke”[MeSH Terms] OR “stroke”[All Fields] OR “brain infarction”[All Fields] OR “cerebrovascular disorder”[All Fields] OR “cerebrovascular disease”[All Fields] OR “CVA”[All Fields] OR “cerebral infarction”[All Fields] OR “ischemic stroke”[All Fields] OR ((“stroke”[MeSH Terms] OR “stroke”[All Fields]) AND (“ischemia”[MeSH Terms] OR “ischemia”[All Fields] OR “ischemic”[All Fields])) OR “cerebrovascular accident”[All Fields]) | 224012
#30 | Search (“risk”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR “risk adjustment”[MeSH Terms] OR “risk assessment”[MeSH Terms] OR (“risk”[All Fields] AND “assessment”[All Fields]) OR “risk assessment”[All Fields] OR (“assessment”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields]) OR (“assessments”[All Fields] AND “benefit”[All Fields] AND “risk”[All Fields])) | 878928
#31 | Search (#3 and #29 and #30) | 884
#32 | Search (#31 and #24) | 141
#33 | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “comparative study”[pt] OR “Epidemiologic Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “observational study” OR “observational studies” OR “cohort”[tw] OR “case control”[tw]) | 3108166
#34 | Search (#31 and #33) | 524
#35 | Search (#32 or #34) | 567
#36 | Search (#5 or #6 or #8 or #14 or #20 or #22) | 2935
#37 | Search (#36 and #26) | 30
#38 | Search (“Endarterectomy, Carotid/statistics and numerical data”[Mesh]) | 844
#39 | Search “Endarterectomy, Carotid/adverse effects”[Mesh] | 1715
#40 | Search (#23 or #38 or #39) | 5681
#41 | Search (harm OR harms OR adverse effect* OR adverse event* OR complication* OR death OR stroke OR “Myocardial Infarction”[Mesh] OR “myocardial infarction” OR (unnecessary AND “carotid endarterectomy”) OR “Kidney Failure, Chronic”[Mesh] OR “Renal Insufficiency”[Mesh] OR “Cranial Nerve Diseases”[Mesh] OR “Cranial Nerve Injuries”[Mesh] OR (neck AND hematoma*)) | 4190723
#42 | Search (#40 and #41) | 4378
#43 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1458299
#44 | Search (#25 or #27) Filters: Humans | 526
#45 | Search (#25 or #27) Filters: Humans; English | 489
#46 | Search (#25 or #27) Filters: Humans; English; Adult: 19+ years | 303
#47 | Search (#46 NOT #43) | 303
#48 | Search (#32 or #34) Filters: Humans | 566
#49 | Search (#32 or #34) Filters: Humans; English | 527
#50 | Search (#32 or #34) Filters: Humans; English; Adult: 19+ years | 453
#51 | Search (#50 NOT #43) | 452
#52 | Search (#36 and #26) Filters: Humans | 30
#53 | Search (#36 and #26) Filters: Humans; English | 28
#54 | Search (#36 and #26) Filters: Humans; English; Adult: 19+ years | 8
#55 | Search (#54 NOT #43) | 8
#56 | Search (#40 and #41) Filters: Humans | 4354
#57 | Search (#40 and #41) Filters: Humans; English | 3928
#58 | Search (#40 and #41) Filters: Humans; English; Adult: 19+ years | 2804
#59 | Search (#58 NOT #43) | 2745
#60 | Search (#47 or #51 or #55 or #59) | 2870
#61 | Search (#60 AND (2013/03/01:2014/03/31[edat])) | 81
#62 | Search (#21 or #31 or #42) | 5889
#63 | Search (#62 AND (“retraction”[All Fields] OR “Retracted Publication”[pt])) | 3

Search | Query | Items found
#1 | Search (“Carotid Stenosis”[Mesh] OR “carotid stenosis” OR “carotid artery stenosis”) | 14210
#2 | Search asymptomatic | 108605
#3 | Search (#1 and #2) | 2859
#4 | Search (“Aspirin”[Mesh] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Pharmacological Action] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Mesh] OR statins[tiab] OR “Platelet Aggregation Inhibitors”[Mesh] OR “Drug Therapy”[Mesh] OR “drug therapy”[subheading]) | 2273767
#5 | Search (#3 and #4) | 257
#6 | Search (“Chemicals and Drugs Category”[Mesh]) | 11386211
#7 | Search (#3 and #6) | 548
#8 | Search (#7 NOT #5) | 344
#9 | Search (“Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR trial[tiab]) | 670734
#10 | Search (#8 and #9) | 20
#11 | Search (#8 and #9) Filters: Humans | 20
#12 | Search (#8 and #9) Filters: Humans; English | 17
#13 | Search (#8 and #9) Filters: Humans; English; Adult: 19+ years | 15
#14 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields])) Filters: Humans; English; Adult: 19+ years | 21895
#15 | Search (#8 and #14) Filters: Humans; English; Adult: 19+ years | 0
#16 | Search (Chlorthalidone[mesh] AND #8) | 0
#17 | Search (Chlorthalidone[mesh] AND #3) | 0
#18 | Search (Hydrochlorothiazide[mesh] AND #3) | 3
#19 | Search (#18 AND (#9 or #14)) | 3
#20 | Search (#18 AND (#9 or #14)) Filters: Humans | 3
#21 | Search (#18 AND (#9 or #14)) Filters: Humans; English | 3
#22 | Search (#18 AND (#9 or #14)) Filters: Humans; English; Adult: 19+ years | 3
#23 | Search (#22 NOT (#5 or #13)) Filters: Humans; English; Adult: 19+ years | 0
#24 | Search (“Lisinopril”[Mesh] AND #3) Filters: Humans; English; Adult: 19+ years | 0
#25 | Search (“Metoprolol”[Mesh] AND #3) Filters: Humans; English; Adult: 19+ years | 0
#26 | Search (#5 and (#9 or #14)) Filters: Humans; English; Adult: 19+ years | 46
#27 | Search (#13 or #22 or #26) Filters: Humans; English; Adult: 19+ years | 61
#28 | Search (#13 or #22 or #26) | 61
#29 | Search (#27 AND (2013/03/01:2014/03/31[edat])) Filters: Humans; English; Adult: 19+ years | 4
#30 | Search ((#5 or #7 or #18) AND (“retraction”[All Fields] OR “Retracted Publication”[pt])) | 0

Appendix B Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Populations | Asymptomatic adults with CAS that is potentially clinically important (defined as 60% to 99% stenosis). Asymptomatic indicates that patients have no significant neurologic symptoms referable to the carotid artery and have not experienced a cerebrovascular event (i.e., a stroke or transient ischemic attack). We will include studies that enroll both symptomatic and asymptomatic subjects, but that analyze the asymptomatic group separately. Among asymptomatic subjects, some trials enroll a minority of subjects who have not had symptoms for some specified time period (e.g., the past 180 days), but who had prior symptoms or cerebrovascular events. Although our focus is on people who have never had cerebrovascular events, we will include such studies if they enroll 70% or more of subjects who never had symptoms referable to the carotid artery and never had a cerebrovascular event into the “asymptomatic” group. | Children and adolescents; symptomatic adults with CAS; adults with history of transient ischemic attacks or stroke; studies of people with carotid occlusion; studies of people undergoing CABG and others confined to a focused population, such as those with radiation exposure or PVD; people with remote CEA or CAAS undergoing surveillance for restenosis.
Setting | Studies conducted in developed countries.
Screening | Screening with carotid duplex ultrasonography, used alone or followed by CTA or MRA with or without confirmatory testing with angiography. Studies that use a single screening test as well as those that use multiple tests in series (e.g., ultrasonography followed by MRA for persons with potentially significant ultrasound findings) will be included. | Physical examination for carotid bruit.
Treatment/management interventions | CEA, CAAS, medical therapy (e.g., aspirin, statins, antiplatelet medications)
Comparisons | KQ 1: Screened versus nonscreened groups. KQ 2: Studies must determine/compare those at increased, average, or decreased risk, or those at higher and lower risk of CAS of 60% to 99%. KQ 3: Studies on accuracy of screening must include a comparison with angiography; studies on reliability of screening must include measures of reproducibility (e.g., test-retest, comparison between different labs or readers). KQ 4: Studies must determine/compare those at increased, average, or decreased risk, or those at higher and lower risk of ipsilateral stroke (KQ 4a) or periprocedural harms from CEA or CAAS (KQ 4b). KQ 5: Medical treatment/usual care. KQ 6: Studies must compare the addition of one or more medications to current standard medical therapy (that includes treatment of traditional risk factors) versus the addition of placebo to current standard medical therapy (that includes treatment of traditional risk factors). KQ 7: Screened versus nonscreened groups or those having angiography versus not having angiography or noncomparative studies reporting rates of harms. KQ 8: Medical treatment/usual care or noncomparative studies reporting rates of harms. | No comparison; nonconcordant historical controls; comparative studies of CEA versus CAAS.
Outcomes | KQs 1, 5, and 6 (health outcomes): CAS-related fatal or nonfatal stroke. Quality of life and functional status. KQ 2 (assessment of risk stratification tools): Adjusted hazard ratio (or risk ratio or odds ratio), discrimination, calibration, reclassification; tools must be externally validated. KQ 3 (diagnostic accuracy and reliability of screening tests): Sensitivity and specificity. KQ 4 (assessment of risk stratification tools): Adjusted hazard ratio (or risk ratio or odds ratio), discrimination, calibration, reclassification; tools must be externally validated. KQ 7 (harms of screening or confirmatory tests): False positives leading to unnecessary treatment, nonfatal stroke, fatal stroke, persistent neurological complications, renal failure. KQ 8 (harms of CEA or CAAS): Perioperative complications, including stroke, death, nonfatal myocardial infarction, cranial nerve injuries. | Restenosis, quality-adjusted life years.
Study designs | KQ 1: Randomized, controlled trials (RCTs) that compare screened versus nonscreened groups. KQ 2: Cohort studies that develop risk stratification tools and then validate the tools using an external population. Studies must follow a cohort of asymptomatic people to develop a tool, derived from a multivariate analysis, predicting risk of CAS. Risk stratification tools (or “risk prediction tools”) must combine multiple variables and allow us to calculate risk for individual patients. KQ 3: Systematic reviews that compare screening tests (ultrasonography, MRA, or CTA) with angiography. Primary studies comparing screening tests with angiography that were published after the included systematic reviews will be included (i.e., bridge searches will be performed to determine what is new since the systematic reviews and whether it is consistent with the systematic reviews). KQ 4: Cohort studies that develop risk stratification tools for adults with asymptomatic CAS and then validate the tools using an external population. Studies must follow a cohort of people with asymptomatic CAS of 60% to 99% to develop a tool, derived from a multivariate analysis, predicting risk of ipsilateral stroke (KQ 4a) or periprocedural harms (KQ 4b). Risk stratification tools (or “risk prediction tools”) must combine multiple variables and allow us to calculate risk for individual patients. Risk stratification tools may include clinical factors (e.g., age, diabetes) and anatomic or imaging predictors (e.g., plaque area or morphology, silent embolic events, contralateral disease). KQ 5: Systematic reviews and RCTs of CEA or CAAS comparing surgical/interventional treatment with medical treatment. KQ 6: Systematic reviews and RCTs. KQ 7: Systematic reviews or multi-institution studies (RCTs or cohort studies) that report harms of screening or confirmatory tests. KQ 8: Systematic reviews or multi-institution studies (RCTs or cohort studies) that report 30-day or longer harms for asymptomatic patients undergoing CEA or CAAS. | All other designs; studies enrolling both symptomatic and asymptomatic patients that don't analyze them separately.
Language | English | Non-English

Note: For the population of interest, we will not rigidly consider those with 60% to 99% CAS as a single homogeneous cohort. Rather, we will include studies enrolling participants beyond that degree of CAS (e.g., 50% to 99% CAS), and we will evaluate the available evidence for various subgroups within that cohort. For example, we will evaluate evidence for those with 80% to 99% CAS, if available.

The settings are limited to developed countries to find evidence most applicable to the United States. Other settings are unlikely to have screening and interventions comparable to those in the United States.

Physical examination for carotid bruit is not included as a screening method under evaluation because an earlier review for the USPSTF (1996) concluded that auscultation for carotid bruits is imperfect, with low sensitivity and specificity and considerable interobserver variation in the interpretation of key auditory characteristics. We scanned the literature published since the 1996 review and found no compelling evidence to suggest that auscultation has become any better as a screening tool to detect clinically significant levels of asymptomatic CAS. Our search identified 51 references, of which 4 reported on the accuracy of screening for CAS by auscultation of the carotid artery. Those studies used varying cutoffs for CAS; minimum cutoff values ranged from 50% to 70%. All studies used ultrasound as the gold standard. The reported sensitivities ranged from 46% to 77%, and specificities ranged from 71% to 98%. Notably, only 2 of the studies were of patients from the general population (one in the United States and the other in France); one study included Swedish patients referred to a hospital for carotid surgery investigation, and the fourth study was among Chinese patients with peripheral vascular disease.