# Summary of Recommendations From Other Groups

Summary of Recommendations for Screening of Asymptomatic CAS Proposed by Expert Panels^a^

Recommendation | Grade/Level of Evidence | Interpretation of Recommendation
American Heart Association/American Stroke Association21
Population screening for asymptomatic carotid stenosis is not recommended. | Class III; Level of Evidence B^b^ | Procedure is not effective and may be harmful; evidence from single randomized trial or nonrandomized study
The usefulness of carotid stenting as an alternative to carotid endarterectomy (CEA) in asymptomatic patients at high risk for the surgical procedure is uncertain. | Class IIb; Level of Evidence C | Recommendation's usefulness and efficacy are less established; only diverging expert opinion, case studies, or standard of care
Joint guidelines from multiple U.S. societies (including the American College of Cardiology, American Heart Association, American Stroke Association, American College of Radiology, and the Society for Vascular Surgery)151
It is reasonable to perform duplex ultrasonography to detect hemodynamically significant carotid stenosis in asymptomatic patients with carotid bruit. | Class IIa; Level of Evidence C^b^ | Recommendation in favor of treatment or procedure; very limited populations have been evaluated
Duplex ultrasonography to detect hemodynamically significant carotid stenosis may be considered in asymptomatic patients with symptomatic peripheral arterial disease, coronary artery disease, or atherosclerotic aortic aneurysm, but because such patients already have an indication for medical therapy to prevent ischemic symptoms, it is unclear whether establishing the additional diagnosis of extracranial carotid and vertebral artery disease in those without carotid bruit would justify actions that affect clinical outcomes. | Class IIb; Level of Evidence C | Recommendation's usefulness and efficacy is less established; only limited populations have been evaluated
Duplex ultrasonography might be considered to detect carotid stenosis in asymptomatic patients without clinical evidence of atherosclerosis who have ≥2 of the following risk factors: hypertension, hyperlipidemia, tobacco smoking, family history in a 1st-degree relative of atherosclerosis manifested before age 60 years, or family history of ischemic stroke. However, it's unclear whether establishing a diagnosis of extracranial carotid and vertebral artery disease would justify actions that affect clinical outcomes. | Class IIb; Level of Evidence C | Recommendation's usefulness and efficacy are less established; only limited populations have been evaluated
Carotid duplex ultrasonography is not recommended for routine screening of asymptomatic patients who have no clinical manifestations of or risk factors for atherosclerosis. | Class III; Level of Evidence C | Recommendation's usefulness and efficacy are less established; only limited populations have been evaluated
Society for Vascular Surgery Guidelines152
Routine screening is not recommended to detect clinically asymptomatic carotid stenosis in the general population. Screening is not recommended for presence of a neck bruit alone without other risk factors. | Grade I, Level of Evidence A^c^ | Risk clearly outweighs benefit, based on high-quality evidence
Screening for asymptomatic clinically significant carotid bifurcation stenosis should be considered in certain groups of patients with multiple risk factors that increase the incidence of disease as long as the patients are fit for and willing to consider carotid intervention if a significant stenosis is discovered. Such groups of patients include those with clinically significant peripheral vascular disease and those age ≥65 years with a history of ≥1 of the following atherosclerotic risk factors: coronary artery disease, smoking, or hypercholesterolemia. | Grade I, Level of Evidence B | Benefit clearly outweighs risk, based on moderate-quality evidence
Carotid screening may be considered in patients prior to coronary artery bypass. Screening is most likely to be fruitful if the patient is age ≥65 years, has left main disease, or has a history of peripheral vascular disease. The strongest indication for screening these patients from the data available is to identify patients at high risk of perioperative stroke. | Grade II, Level of Evidence B | Benefits and risks are more closely matched and more dependent on specific clinical scenarios as well as physician and patient preferences, based on moderate quality evidence

a These selected recommendations are most relevant to this review and not meant to be comprehensive. Some recommendations have been summarized.

b Recommendations are made using the GRADE (Grades of Recommendation Assessment, Development and Evaluation) system.

c Recommendations based on ACCF/AHA Task Force on Practice Guidelines.