# References

1 U.S. Preventive Services Task Force. Screening for Hepatitis B Virus Infection. 2004. www.uspreventiveservicestaskforce.org/uspstf/uspshepb.htm.
2 Research Triangle Institute-University of North Carolina. Screening for Hepatitis B Virus Infection: A Brief Evidence Update for the U.S. Preventive Services Task Force. 2004. www.uspreventiveservicestaskforce.org/3rduspstf/hepbscr/hepbup.pdf.
3 Lin K, Vickery J. Screening for hepatitis B virus infection in pregnant women: evidence for the United States Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(12):874-6. [pmid: 19528566].
4 United States Preventive Services Task Force. Screening for hepatitis B virus infection in pregnancy. Ann Intern Med. 2009;150:869-73. [pmid: 19528565].
5 Lin KW, Kirchner JT. Hepatitis B. Am Fam Physician. 2004;69(1):75-82. [pmid: 14727820].
6 Mast EE, Weinbaum CM, Fiore AE, et al. A comprehensive immunization strategy to eliminate transmission of hepatitis B virus infection in the United States: recommendations of the Advisory Committee on Immunization Practices (ACIP) Part II: immunization of adults. MMWR. 2006;55(RR-16):1-33. quiz CE1-4. [pmid: 17159833].
7 Centers for Disease Control and Prevention. Interpretation of Hepatitis B Serologic Test Results. 2005. www.cdc.gov/hepatitis/hbv/pdfs/serologicchartv8.pdf. 14 May 2014.
8 Dusheiko G, Antonakopoulos N. Current treatment of hepatitis B. Gut. 2008;57(1):105-24. [pmid: 17502343].
9 Mast EE, Margolis HS, Fiore AE, et al. A comprehensive immunization strategy to eliminate transmission of hepatitis B virus infection in the United States: recommendations of the Advisory Committee on Immunization Practices (ACIP) part 1: immunization of infants, children, and adolescents. MMWR Recomm Rep. 2005;54(RR-16):1-31. [pmid: 16371945].
10 Centers for Disease Control and Prevention. Viral Hepatitis Statistics and Surveillance: Disease Burden from Viral Hepatitis A, B, and C in the United States. 2013. www.cdc.gov/hepatitis/Statistics/index.htm. 14 May 2014.
11 Centers for Disease Control and Prevention. Viral Hepatitis Surveillance—United States, 2010. www.cdc.gov/hepatitis/Statistics/2010Surveillance/. 14 May 2014.
12 Ioannou GN. Hepatitis B virus in the United States: infection, exposure, and immunity rates in a nationally representative survey. Ann Intern Med. 2011;154(5):319-28. [pmid: 21357909].
13 Centers for Disease Control and Prevention. Viral Hepatitis Statistics & Surveillance: Table 3.5 Number and rate of deaths with hepatitis B listed as a cause of death, by demographic characteristic and year — United States, 2006–2010. 2013. www.cdc.gov/hepatitis/Statistics/2011Surveillance/Table3.5.htm.
14 Centers for Disease Control and Prevention. Hepatitis B General Fact Sheet. 2010. www.cdc.gov/hepatitis/hbv/pdfs/hepbgeneralfactsheet.pdf.
15 Weinbaum CM, Williams I, Mast EE, et al. Recommendations for identification and public health management of persons with chronic hepatitis B virus infection. MMWR. 2008;57(RR-8):1-20. [pmid: 18802412].
16 Fattovich G, Bortolotti F, Donato F. Natural history of chronic hepatitis B: special emphasis on disease progression and prognostic factors. J Hepatol. 2008;48(2):335-52. [pmid: 18096267].
17 Chen CJ, Yang HI, Su J, et al. Risk of hepatocellular carcinoma across a biological gradient of serum hepatitis B virus DNA level. JAMA. 2006;295(1):65-73. [pmid: 16391218].
18 Iloeje UH, Yang HI, Su J, et al. Predicting cirrhosis risk based on the level of circulating hepatitis B viral load. Gastroenterology. 2006;130(3):678-86. [pmid: 16530509].
19 Kowdley KV, Wang CC, Welch S, et al. Prevalence of chronic hepatitis B among foreign-born persons living in the United States by country of origin. Hepatology. 2012;56(2):422-33. [pmid: 22105832].
20 Mitchell T, Armstrong GL, Hu DJ, et al. The increasing burden of imported chronic hepatitis B—United States, 1974–2008. PLoS ONE. 2011;6(12):e27717. [pmid: 22163270].
21 Sorrell MF, Belongia EA, Costa J, et al. National Institutes of Health Consensus Development Conference Statement: Management of Hepatitis B. Ann Intern Med. 2009;150:104-10. [pmid: 19124811].
22 Quaglio G, Lugoboni F, Mezzelani P, et al. Hepatitis vaccination among drug users. Vaccine. 2006;24(15):2702-9. [pmid: 16436307].
23 Wasley A, Grytdal S, Gallagher K. Surveillance for acute viral hepatitis—United States, 2006. MMWR Surveill Summ. 2008;57(2):1-24. [pmid: 18354374].
24 World Health Organization. WHO Vaccine Preventable Diseases Monitoring System. 2013. http://www.who.int/immunization/monitoring_surveillance/burden/VPDs/en/.
25 Centers for Disease C Prevention. Implementation of newborn hepatitis B vaccination—worldwide, 2006. MMWR. 2008;57(46):1249-52. [pmid: 19023261].
26 Zanetti AR, Van Damme P, Shouval D. The global impact of vaccination against hepatitis B: a historical overview. Vaccine. 2008;26(49):6266-73. [pmid: 18848855].
27 Lok AS, McMahon BJ. American Association for the Study of Liver Diseases (AASLD) Practice Guideline Update: Chronic Hepatitis B: Update 2009. Hepatology. 2009;50:661. [pmid: 19714720].
28 Keeffe EB, Dieterich DT, Han SHB, et al. A treatment algorithm for the management of chronic hepatitis B virus infection in the United States: 2008 update. Clin Gastroenterol Hepatol. 2008;6(12):1315-41. [pmid: 18845489].
29 Hoofnagle JH, Doo E, Liang TJ, et al. Management of hepatitis B: summary of a clinical research workshop. Hepatology. 2007;45(4):1056-75. [pmid: 17393513].
30 Lok AS, McMahon BJ. Chronic hepatitis B. Hepatology. 2007;45(2):507-39. [pmid: 17256718].
31 Institute of Medicine. Report Brief January 2010: Hepatitis and Liver Cancer: A National Strategy for Prevention and Control of Hepatitis B and C. 2010. www.iom.edu/Reports/2010/Hepatitis-and-Liver-Cancer-A-National-Strategy-for-Prevention-and-Control-of-Hepatitis-B-and-C.aspx/.
32 Harris RP, Helfand M, Wolff SH, et al. Current methods of the United States Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
33 U.S. Preventive Services Task Force. Procedure Manual. AHRQ Publication No. 08-05118. 2008. www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.
34 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. Br Med J. 2003;327(7414):557-60. [pmid: 12958120].
35 Spenatto N, Boulinguez S, Mularczyk M, et al. Hepatitis B screening: who to target? A French sexually transmitted infection clinic experience. J Hepatol. 2013;58(4):690-7. [pmid: 23220369].
36 Chen W, Gluud C. Vaccines for preventing hepatitis B in health-care workers. Cochrane Database Syst Rev. 2005;(4):CD000100. [pmid: 16235273].
37 Szmuness W, Stevens CE, Harley EJ, et al. Hepatitis B vaccine: demonstration of efficacy in a controlled clinical trial in a high-risk population in the United States. N Engl J Med. 1980;303(15):833-41. [pmid: 6997738].
38 Coutinho RA, Lelie N, Albrecht-Van Lent P, et al. Efficacy of a heat inactivated hepatitis B vaccine in male homosexuals: outcome of a placebo controlled double blind trial. Br Med J Clin Res Ed. 1983;286(6374):1305-8. [pmid: 6404440].
39 Francis DP, Hadler SC, Thompson SE, et al. The prevention of hepatitis B with vaccine. Report of the Centers for Disease Control multi-center efficacy trial among homosexual men. Ann Intern Med. 1982;97(3):362-6. [pmid: 6810736].
40 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-negative chronic hepatitis B. N Engl J Med. 2003;348(9):800-7. [pmid: 12606734].
41 Jonas MM, Kelly D, Pollack H, et al. Safety, efficacy, and pharmacokinetics of adefovir dipivoxil in children and adolescents (age 2 to <18 years) with chronic hepatitis B. Hepatology. 2008;47(6):1863-71. [pmid: 18433023].
42 Marcellin P, Chang TT, Lim SG, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-positive chronic hepatitis B. N Engl J Med. 2003;348(9):808-16. [pmid: 12606735].
43 Zeng M, Mao Y, Yao G, et al. A double-blind randomized trial of adefovir dipivoxil in Chinese subjects with HBeAg-positive chronic hepatitis B. Hepatology. 2006;44(1):108-16. [pmid: 16799983].
44 Bayraktar Y, Uzunalimoglu B, Arslan S, et al. Effects of recombinant alpha interferon on chronic active hepatitis B: preliminary results. Gut. 1993;34(2 Suppl):S101. [pmid: 8314468].
45 Hadziyannis S, Bramou T, Makris A, et al. Interferon alfa-2b treatment of HBeAg negative/serum HBV DNA positive chronic active hepatitis type B. J Hepatol. 1990;11(Suppl 1):S133-6. [pmid: 2079571].
46 Lampertico P, Del Ninno E, Manzin A, et al. A randomized, controlled trial of a 24-month course of interferon alfa 2b in patients with chronic hepatitis B who had hepatitis B virus DNA without hepatitis B e antigen in serum. Hepatology. 1997;26(6):1621-5. [pmid: 9398007].
47 Muller R, Baumgarten R, Markus R, et al. Treatment of chronic hepatitis B with interferon alfa-2b. J Hepatol. 1990;11(1):S137-40. [pmid: 2079572].
48 Perez V, Tanno H, Villamil F, et al. Recombinant interferon alfa-2b following prednisone withdrawal in the treatment of chronic type B hepatitis. J Hepatol. 1990;11(Suppl 1):S113-7. [pmid: 2079567].
49 Perrillo RP, Schiff ER, Davis GL, et al. A randomized, controlled trial of interferon alfa-2b alone and after prednisone withdrawal for the treatment of chronic hepatitis B. The Hepatitis Interventional Therapy Group. N Engl J Med. 1990;323(5):295-301. [pmid: 2195346].
50 Sarin SK, Guptan RC, Thakur V, et al. Efficacy of low-dose alpha interferon therapy in HBV-related chronic liver disease in Asian Indians: a randomized controlled trial. J Hepatol. 1996;24(4):391-6. [pmid: 8738724].
51 Waked I, Amin M, Abd el Fattah S, et al. Experience with interferon in chronic hepatitis B in Egypt. J Chemother. 1990;2(5):310-8. [pmid: 2090770].
52 Ali HY. Trial of lamivudine in hepatitis B surface antigen carriers with persistent hepatitis B core IgM antibody. Saudi Med J. 2003;24(9):996-9. [pmid: 12973486].
53 Bozkaya H, Yurdaydin C, Idilman R, et al. Lamivudine treatment in HBeAg-negative chronic hepatitis B patients with low level viraemia. Antivir Ther. 2005;10(2):319-25. [pmid: 15865226].
54 Chan HLY, Wang H, Niu J, et al. Two-year lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B: a double-blind, placebo-controlled trial. Antivir Ther. 2007;12(3):345-53. [pmid: 17591024].
55 Dienstag JL, Schiff ER, Wright TL, et al. Lamivudine as initial treatment for chronic hepatitis B in the United States. N Engl J Med. 1999;341(17):1256-63. [pmid: 10528035].
56 Lai CL, Ching CK, Tung AK, et al. Lamivudine is effective in suppressing hepatitis B virus DNA in Chinese hepatitis B surface antigen carriers: a placebo-controlled trial. Hepatology. 1997;25(1):241-4. [pmid: 8985298].
57 Lai CL, Chien RN, Leung NW, et al. A one-year trial of lamivudine for chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. N Engl J Med. 1998;339(2):61-8. [pmid: 9654535].
58 Tassopoulos NC, Volpes R, Pastore G, et al. Efficacy of lamivudine in patients with hepatitis B e antigen-negative/hepatitis B virus DNA-positive (precore mutant) chronic hepatitis B. Lamivudine Precore Mutant Study Group. Hepatology. 1999;29(3):889-96. [pmid: 10051494].
59 Yalcin K, Degertekin H, Kokoglu OF, et al. A three-month course of lamivudine therapy in HBeAg-positive hepatitis B patients with normal aminotransferase levels. Turk J Gastroenterol. 2004;15(1):14-20. [pmid: 15264116].
60 Yao G, Wang B, Cui Z, et al. A randomized double-blind placebo-controlled study of lamivudine in the treatment of patients with chronic hepatitis B virus infection. Chin Med J. 1999;112(5):387-91. [pmid: 11593504].
61 Murray KF, Szenborn L, Wysocki J, et al. Randomized, placebo-controlled trial of tenofovir disoproxil fumarate in adolescents with chronic hepatitis B. Hepatology. 2012;56(6):2018-26. [pmid: 22544804].
62 Lai CL, Lim SG, Brown NA, et al. A dose-finding study of once-daily oral telbivudine in HBeAg-positive patients with chronic hepatitis B virus infection. Hepatology. 2004;40(3):719-26. [pmid: 15349912].
63 Jonas MM, Block JM, Haber BA, et al. Treatment of children with chronic hepatitis B virus infection in the United States: patient selection and therapeutic options. Hepatology. 2010;52(6):2192-205. [pmid: 20890947].
64 Chang TT, Gish RG, de Man R, et al. A comparison of entecavir and lamivudine for HBeAg-positive chronic hepatitis B. N Engl J Med. 2006;354(10):1001-10. [pmid: 16525137].
65 Gish RG, Lok AS, Chang TT, et al. Entecavir therapy for up to 96 weeks in patients with HBeAg-positive chronic hepatitis B. Gastroenterology. 2007;133(5):1437-44. [pmid: 17983800].
66 Chang TT, Chao YC, Gorbakov VV, et al. Results of up to 2 years of entecavir vs lamivudine therapy in nucleoside-naive HBeAg-positive patients with chronic hepatitis B. J Viral Hepat. 2009;16(11):784-9. [pmid: 19457141].
67 Lai CL, Shouval D, Lok AS, et al. Entecavir versus lamivudine for patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2006;354(10):1011-20. [pmid: 16525138].
68 Lai CL, Rosmawati M, Lao J, et al. Entecavir is superior to lamivudine in reducing hepatitis B virus DNA in patients with chronic hepatitis B infection. Gastroenterology. 2002;123(6):1831-8. [pmid: 12454840].
69 Ren FY, Piao DM, Piao XX. A one-year trial of entecavir treatment in patients with HBeAg-positive chronic hepatitis B. World J Gastroenterol. 2007;13(31):4264-7. [pmid: 17696259].
70 Lau GK, Piratvisuth T, Luo KX, et al. Peginterferon Alfa-2a, lamivudine, and the combination for HBeAg-positive chronic hepatitis B. N Engl J Med. 2005;352(26):2682-95. [pmid: 15987917].
71 Marcellin P, Lau GK, Bonino F, et al. Peginterferon alfa-2a alone, lamivudine alone, and the two in combination in patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2004;351(12):1206-17. [pmid: 15371578].
72 Marcellin P, Heathcote EJ, Buti M, et al. Tenofovir disoproxil fumarate versus adefovir dipivoxil for chronic hepatitis B. N Engl J Med. 2008;359(23):2442-55. [pmid: 19052126].
73 Lin SM, Sheen IS, Chien RN, et al. Long-term beneficial effect of interferon therapy in patients with chronic hepatitis B virus infection. Hepatology. 1999;29(3):971-5. [pmid: 10051505].
74 Liaw YF, Lin SM, Chen TJ, et al. Beneficial effect of prednisolone withdrawal followed by human lymphoblastoid interferon on the treatment of chronic type B hepatitis in Asians: a randomized controlled trial. J Hepatol. 1994;20(2):175-80. [pmid: 8006397].
75 Mazzella G, Saracco G, Festi D, et al. Long-term results with interferon therapy in chronic type B hepatitis: a prospective randomized trial. Am J Gastroenterol. 1999;94(8):2246-50. [pmid: 10445557].
76 Liaw YF, Sung JJ, Chow WC, et al. Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. 2004;351(15):1521-31. [pmid: 15470215].
77 Yu HB, Liu EQ, Lu SM, et al. Treatment with peginterferon versus interferon in Chinese patients with hepatitis B. Biomed Pharmacother. 2010;64(8):559-64. [pmid: 20630699].
78 Yao GB. Management of hepatitis B in China. J Med Virol. 2000;61(3):392-7. [pmid: 10861652].
79 Yao GB, Zhu M, Cui ZY, et al. A 7-year study of lamivudine therapy for hepatitis B virus e antigen-positive chronic hepatitis B patients in China. J Dig Dis. 2009;10(2):131-7. [pmid: 19426396].
80 Andreone P, Gramenzi A, Cursaro C, et al. High risk of hepatocellular carcinoma in anti-HBe positive liver cirrhosis patients developing lamivudine resistance. J Viral Hepat. 2004;11(5):439-42. [pmid: 15357649].
81 Baltayiannis G, Katsanos K, Karayiannis P, et al. Interferon-α therapy in HBeAg-negative chronic hepatitis B: a long-term prospective study from north-western Greece. Aliment Pharmacol Ther. 2006;24(3):525-33. [pmid: 16886919].
82 Di Marco V, Marzano A, Lampertico P, et al. Clinical outcome of HBeAg-negative chronic hepatitis B in relation to virological response to lamivudine. Hepatology. 2004;40(4):883-91. [pmid: 15382125].
83 Fattovich G, Giustina G, Realdi G, et al. Long-term outcome of hepatitis B e antigen-positive patients with compensated cirrhosis treated with interferon alfa. European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. 1997;26(5):1338-42. [pmid: 9362381].
84 Hui CK, Leung N, Shek WH, et al. Changes in liver histology as a “surrogate” end point of antiviral therapy for chronic HBV can predict progression to liver complications. J Clin Gastroenterol. 2008;42(5):533-8. [pmid: 18344885].
85 Lampertico P, Del Ninno E, Vigano M, et al. Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. 2003;37(4):756-63. [pmid: 12668967].
86 Niederau C, Heintges T, Lange S, et al. Long-term follow-up of HBeAg-positive patients treated with interferon alfa for chronic hepatitis B. N Engl J Med. 1996;334(22):1422-7. [pmid: 8618580].
87 Papatheodoridis GV, Manesis E, Hadziyannis SJ. The long-term outcome of interferon-alpha treated and untreated patients with HBeAg-negative chronic hepatitis B. J Hepatol. 2001;34(2):306-13. [pmid: 11281561].
88 Papatheodoridis GV, Manolakopoulos S, Touloumi G, et al. Virological suppression does not prevent the development of hepatocellular carcinoma in HBeAg-negative chronic hepatitis B patients with cirrhosis receiving oral antiviral(s) starting with lamivudine monotherapy: results of the nationwide HEPNET. Greece cohort study. Gut. 2011;60(8):1109-16. [pmid: 21270118].
89 Lau DT, Everhart J, Kleiner DE, et al. Long-term follow-up of patients with chronic hepatitis B treated with interferon alfa. Gastroenterology. 1997;113(5):1660-7. [pmid: 9352870].
90 Shamliyan TA, Johnson JR, MacDonald R, et al. Systematic review of the literature on comparative effectiveness of antiviral treatments for chronic hepatitis B infection. J Gen Intern Med. 2011;26(3):326-39. [pmid: 21203860].
91 Miyake Y, Kobashi H, Yamamoto K. Meta-analysis: the effect of interferon on development of hepatocellular carcinoma in patients with chronic hepatitis B virus infection. J Gastroenterol. 2009;44(5):470-5. [pmid: 19308310].
92 Zhang QQ, An X, Liu YH, et al. Long-term nucleos(t)ide analogues therapy for adults with chronic hepatitis B reduces the risk of long-term complications: a meta-analysis. Virol J. 2011;8:72. [pmid: 21324130].
93 Lai CL, Yuen MF. Prevention of hepatitis b virus-related hepatocellular carcinoma with antiviral therapy. Hepatology. 2013;57(1):399-408. [pmid: 22806323].
94 Wong GLH, Yiu KKL, Wong VWS, et al. Meta-analysis: reduction in hepatic events following interferon-alfa therapy of chronic hepatitis B. Aliment Pharmacol Ther. 2010;32(9):1059-68. [pmid: 20807216].
95 Jin H, Pan N, Mou Y, et al. Long-term effect of interferon treatment on the progression of chronic hepatitis B: bayesian meta-analysis and meta-regression. Hepatol Res. 2011;(41):512-23. [pmid: 21501353].
96 Papatheodoridis GV, Lampertico P, Manolakopoulos S, et al. Incidence of hepatocellular carcinoma in chronic hepatitis B patients receiving nucleos(t)ide therapy: a systematic review. J Hepatol. 2010;53(2):348-56. [pmid: 20483498].
97 Woo G, Tomlinson G, Nishikawa Y, et al. Tenofovir and entecavir are the most effective antiviral agents for chronic hepatitis B: a systematic review and Bayesian meta-analyses. Gastroenterology. 2010;139(4):1218-29. [pmid: 20600036].
98 Liang J, Tang YF, Wu FS, et al. Entecavir versus lamivudine for the treatment of chronic hepatitis B: a systematic review. Pharmazie. 2012;67(11):883-90. [pmid: 23210236].
99 Dakin H, Fidler C, Harper C. Mixed treatment comparison meta-analysis evaluating the relative efficacy of nucleos(t)ides for treatment of nucleos(t)ide-naive patients with chronic hepatitis B. Value Health. 2010;13(8):934-45. [pmid: 20825624].
100 Zhao SH, Liu EQ, Cheng DX, et al. Comparison of entecavir and adefovir for the treatment of chronic hepatitis B. Braz J Infect Dis. 2012;16(4):366-72. [pmid: 22846126].
101 Chou R, Hartung D, Rahman B, et al. Comparative effectiveness of antiviral treatment for hepatitis C virus infection in adults: a systematic review. Ann Intern Med. 2013;158:114-23. [pmid: 23437439].
102 Chang MH, Chen CJ, Lai MS, et al. Universal hepatitis B vaccination in Taiwan and the incidence of hepatocellular carcinoma in children. Taiwan Childhood Hepatoma Study Group. N Engl J Med. 1997;336(26):1855-9. [pmid: 9197213].
103 Lim SG, Mohammed R, Yuen MF, et al. Prevention of hepatocellular carcinoma in hepatitis B virus infection. J Gastroenterol Hepatol. 2009;24(8):1352-7. [pmid: 19702903].
104 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(02):138-44. [pmid: 22559755].
105 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769-76. [pmid: 16086467].
106 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinom-a. J Cancer Res Clin Oncol. 2004;130(7):417-22. [pmid: 15042359].
107 Chen JG, Parkin DM, Chen QG, et al. Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204-9. [pmid: 14738659].
108 Centers for Disease Control and Prevention. Surveillance for acute viral hepatitis—United States, 2007. MMWR Surveill Summ. 2009;58(SS-3). www.cdc.gov/mmwr/pdf/ss/ss5803.pdf.
109 Wasley A, Kruszon-Moran D, Kuhnert W, et al. The prevalence of hepatitis B virus infection in the United States in the era of vaccination. J Infect Dis. 2010;202(2):192-201. [pmid: 20533878].
110 Ott JJ, Stevens GA, Groeger J, et al. Global epidemiology of hepatitis B virus infection: new estimates of age-specific HBsAg seroprevalence and endemicity. Vaccine. 2012;30(12):2212-9. [pmid: 22273662].
111 Cox N, Tillmann H. Emerging pipeline drugs for hepatitis B infection. Expert Opin Emerg Drugs. 2011;16(4):713-29. [pmid: 22195605].
112 Lok AS, McMahon BJ. Chronic hepatitis B: update 2009. Hepatology. 2009;50(3):661-2. [pmid: 19714720].
113 Kwon H, Lok AS. Hepatitis B therapy. Nat Rev Gastroenterol Hepatol. 2011;8(5):275-84. [pmid: 21423260].
114 Grimm D, Thimme R, Blum HE. HBV life cycle and novel drug targets. Hepatol Int. 2011;5(2):644-53. [pmid: 21484123].
115 Centers for Disease Control and Prevention. Screening for chronic hepatitis B among Asian/Pacific Islander populations—New York City, 2005. MMWR. 2006;55(18):505-9. [pmid: 16691180].
116 Lin SY, Chang ET, So SK. Why we should routinely screen Asian American adults for hepatitis B: a cross-sectional study of Asians in California. Hepatology. 2007;46(4):1034-40. [pmid: 17654490].
117 Cohen MS, Chen YQ, McCauley M, et al. Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011;365(6):493-505. [pmid: 21767103].
118 Lai CL, Yuen MF. The natural history and treatment of chronic hepatitis B: a critical evaluation of standard treatment criteria and end points. Ann Intern Med. 2007;147(1):58-61. [pmid: 17606962].