# Discussion

## Summary of Review Findings

As in the 2004 USPSTF evidence review, we found no direct evidence on effects of screening for HBV infection versus no screening on clinical outcomes.2 The evidence reviewed in this update is summarized in Table 13. Additional areas addressed in this review that were not covered in the 2004 USPSTF review are benefits and harms of antiviral treatments, the association between improvement in intermediate outcomes following antiviral therapy and subsequent clinical outcomes, and effects of education and behavior change counseling.

Table 13 Summary of Evidence

Key Question | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality
1. What are the benefits of screening for HBV versus no screening in asymptomatic, nonpregnant adolescents and adults on morbidity, mortality, and disease transmission? | No studies | No studies | N/A | N/A | No evidence | No evidence
2. What are the harms of screening for HBV infection (e.g., labeling, anxiety, and harms of confirmatory tests, including biopsy)? | No studies | No studies | N/A | N/A | No evidence | No evidence
3. How well do different screening strategies identify individuals with HBV infection (e.g., strategies that target persons from high-prevalence countries, men who have sex with men, injection drug users, immunization history, or other risk factors)? | One cross-sectional study | Evidence available from only 1 study with methodological limitations | N/A | Study conducted in high-risk sexually transmitted disease clinic attendees | One study found screening targeted at persons born in countries with higher chronic HBV prevalence, men, and unemployed persons identified 98% (48/49) of infections; number needed to screen to identify 1 case of HBV infection of 82. | Poor
4. In nonpregnant adolescents and adults with no evidence of HBV immunity on screening, how effective is HBV vaccination for improving clinical outcomes? | No studies with evidence on long-term clinical outcomes | No evidence on long-term clinical outcomes | Moderate | Studies conducted in high-risk populations (health care workers or MSM) and/or children | Vaccination is associated with decreased risk of HBV acquisition in health care workers (4 trials; RR, 0.51; 95% CI, 0.35 to 0.73) and men who have sex with men (4 trials; RR, 0.21; 95% CI, 0.11 to 0.39) based on serologic markers. Studies did not evaluate the effectiveness of HBV vaccination on long-term clinical outcomes. | Fair
5. In nonpregnant adolescents and adults with chronic HBV infection, how effective is antiviral treatment at improving intermediate outcomes (virological or histological improvement or clearance of HBeAg)? | 30 RCTs | Study duration and patient characteristics varied widely Few good-quality studies | High | About half the studies conducted outside of the United States/Europe and about a third enrolled HBeAg-negative patients | Antiviral treatment was more effective than placebo or no treatment for HBeAg loss or seroconversion (10 trials; RR, 2.1; 95% CI, 1.6 to 2.9; I^2^=4%), HBsAg loss/seroconversion (12 trials; RR, 2.4; 95% CI, 1.2 to 4.9; I^2^=0%), ALT normalization (12 trials; RR, 2.5; 95% CI, 2.1 to 3.0; I^2^=27%), loss of HBV DNA (9 trials; RR, 7.2; 95% CI, 3.2 to 16; I^2^=58%) and histologic improvement (7 trials; RR, 2.1; 95% CI, 1.8 to 2.6; I^2^=0%). Results were generally consistent across specific antiviral drugs. Entecavir and pegylated interferon alfa-2a were each associated with greater likelihood of achieving some intermediate virological and other outcomes than lamivudine, based on few (1 to 4) trials. | Fair
6. In nonpregnant adolescents and adults with chronic HBV infection, how effective is antiviral treatment at improving health outcomes? | 16 RCTs | Many studies were small, with few events Only 1 good-quality study | Moderate | About half the studies conducted outside of the United States/Europe and about a third enrolled HBeAg-negative patients | Estimates for incident cirrhosis (3 trials; RR, 0.70; 95% CI, 0.33 to 1.46; I^2^=0%), hepatocellular carcinoma (5 trials; RR, 0.57; 95% CI, 0.32 to 1.04; I^2^=2%), and mortality (5 trials; RR, 0.55; 95% CI, 0.18 to 1.71; I^2^=43%) all favored antiviral therapy over placebo, although differences were not statistically significant. There were too few clinical events in head-to-head trials of entecavir or pegylated interferon alfa-2a vs. lamivudine or pegylated interferon vs. nonpegylated interferon to determine effects on clinical outcomes. | Fair
7. In nonpregnant adolescents and adults with chronic HBV infection, how effective is education or behavior change counseling in reducing transmission and improving health outcomes? | No studies | No evidence | N/A | N/A | No evidence | No evidence
8. What are the harms associated with antiviral treatment for HBV infection? | 29 RCTs | Many studies were small, with few events | High | Many studies conducted outside of the United States/Europe | There were no differences between treatment and control groups for serious adverse effects (12 trials; RR 0.8; 95% CI, 0.6 to 1.1; I^2^=0%) or any adverse events (7 trials; RR, 0.96; 95% CI, 0.9 to 1.0; I^2^=0%). Antiviral therapy was associated with more withdrawals due to adverse effects, but estimates were imprecise due to small numbers of events (9 trials; RR, 3.97; 95% CI, 1.4 to 11; I^2^=0%). Results were generally consistent across specific antiviral drugs. In 2 head-to-head trials, pegylated interferon alfa-2a was associated with greater risk of serious adverse events (RR, 2.1; 95% CI, 1.0 to 4.5; I^2^=0%) and withdrawal due to adverse events (RR, 7.6; 95% CI, 1.1 to 52; I^2^=38%) vs. lamivudine. | Fair
KQ 9. Do improvements in intermediate outcomes improve final health outcomes? | 10 observational studies | High variability in patient characteristics and outcomes evaluated No studies were good quality; 3 were poor quality and failed to address important confounders | Moderate | One study excluded patients with cirrhosis, 2 studies included only patients with cirrhosis, and in the remainder the proportion with cirrhosis ranged from 12% to 60% | Ten observational studies found an association between various intermediate outcomes and clinical outcomes (death, hepatocellular carcinoma, or a composite clinical outcome), but variability in patient populations, intermediate and clinical outcomes evaluated, and methodological limitations make it difficult to draw strong conclusions. In some studies, results were not statistically significant. | Poor

Abbreviations: ALT = alanine aminotransferase; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; MSM = men who have sex with men; N/A = not applicable; RCT = randomized, controlled trial; RR = relative risk.

Identification of chronic HBV infection is based on interpretation of serologic markers and has previously been assessed by the USPSTF as accurate (sensitivity and specificity greater than 98%).4 Evidence on the usefulness of different screening strategies for identifying persons with HBV infection is limited to a single fair-quality cross-sectional study performed in France.35 It found that an HBV screening strategy in an STD clinic that focused on testing only persons born in higher prevalence countries would have missed about two-thirds of patients. A broader strategy that also tested men and unemployed persons identified almost all patients with HBV infection in this population while screening about two-thirds of the population. Well-established risk factors, such as injection drug use and high-risk sexual behaviors, were not predictive in this study, underscoring the need for further validation, and the applicability of findings to screening in typical primary care settings in the United States may be limited.

Data from randomized trials suggest that antiviral therapy may be more effective than placebo for reducing risk of clinical outcomes associated with HBV infection, such as incident cirrhosis, hepatocellular carcinoma, and mortality.41,43,46,49,51,54,55,57,73,75,76 However, results were based on small numbers of trials, differences were not statistically significant, trials were underpowered, and pooled estimates were imprecise due to small numbers of events. In addition, the patient populations evaluated in the trials differed on important characteristics (such as severity of baseline liver disease and presence of HBeAg), the trials evaluated different antiviral drugs, few trials evaluated currently recommended first-line antivirals (entecavir, pegylated interferon alfa-2a, and tenofovir), and duration of followup varied, making it difficult to draw strong conclusions. Although the pooled estimate for hepatocellular carcinoma nearly reached statistical significance (5 trials; RR, 0.57; 95% CI, 0.32 to 1.04; I^2^=2%),46,54,73,75,76 it was heavily influenced by results from one Asian trial that primarily enrolled patients with more advanced liver disease, potentially reducing its applicability to screen-detected U.S. populations.76 Although some head-to-head trials of first-line versus older antivirals reported mortality or hepatocellular cancer, none was designed to evaluate clinical outcomes and all were severely underpowered. Our findings are similar to those from a recent systematic review that focused on results from randomized trials.90 Although other reviews91-96 reported an association between use of antiviral therapy and improvement in clinical outcomes, results were primarily based on observational studies, including studies that did not adjust well for confounders.

Evidence is stronger in showing that antiviral therapy is more effective than placebo or no treatment for various intermediate outcomes, such as HBeAg loss or seroconversion (10 trials; RR, 2.1; 95% CI, 1.6 to 2.9; I^2^=4%),42-44,48,50,51,55,59-61 HBsAg loss or seroconversion (12 trials; RR, 2.4; 95% CI, 1.2 to 4.9; I^2^=0%),44,46,48-52,54,55,58,61 ALT normalization (12 trials; RR, 2.5; 95% CI, 2.1 to 3.0; I^2^=27%),38-42,46,51-53,55,58,59 reduction in HBV DNA (9 trials; RR, 7.2; 95% CI, 3.2 to 16; I^2^=58%),40,43,48,50,54,55,59-61 histological improvement (7 trials; RR, 2.1; 95% CI, 1.8 to 2.6; I^2^=0%),40,42,46,51,54,55,57 and various composite outcomes. Results were generally consistent when analyses were stratified by individual drug, although some estimates were imprecise and not statistically significant. Like other recently conducted systematic reviews, this review also found some evidence suggesting that the currently recommended first-line drugs tenofovir and entecavir are more effective than lamivudine for various intermediate outcomes.90,97-100

The degree to which improvements in intermediate outcomes are associated with improved clinical outcomes is less clear. Although observational studies generally found an association between experiencing an improved intermediate outcome following antiviral therapy and death, hepatocellular carcinoma, or a composite clinical outcome, results were not statistically significant in all studies, and there were important differences across studies in the intermediate and clinical outcomes evaluated, variability in patient populations, and methodological limitations (including failure to control for key confounders in some studies), precluding strong conclusions.80-89

Antiviral therapy was associated with greater risk of withdrawal due to adverse events than placebo (9 trials; RR, 4.0; 95% CI, 1.4 to 11; I^2^=0%),40-42,46,48,49,52,58,60 but trials found no difference in risk of serious adverse events (12 trials; RR, 0.8; 95% CI, 0.6 to 1.1; I^2^=0%)40,42,54-62,76 or experiencing any adverse event (7 trials; RR, 0.96; 95% CI, 0.9 to 1.0; I^2^=0%).40,57,58,60-62,76 Head-to-head trials found pegylated interferon alfa-2a associated with increased risk of serious adverse events and withdrawal due to adverse events versus lamivudine,70,71 consistent with the known high prevalence of adverse events with interferon-based therapies.101 In general, adverse events associated with antiviral therapy, including interferon, are self-limited and resolve following discontinuation of the drug.

Evidence on effects on clinical outcomes of interventions other than antiviral therapy as a result of screening was limited. Trials of health care workers and men who have sex with men found HBV vaccination of adults with no evidence of HBV immunity associated with decreased risk of HBV acquisition based on serologic and biochemical markers but did not evaluate long-term clinical outcomes. Observational studies in high-prevalence countries indicate that implementation of universal HBV vaccination of newborns and children is associated with reduced rates of hepatocellular carcinoma and other clinical outcomes related to chronic HBV infection, but they were outside the scope of this review.26,102,103 We identified no trials on the effectiveness of education or behavior change counseling in patients with chronic HBV infection for reducing transmission or improving health outcomes.

## Limitations

We excluded non–English-language articles, which could result in language bias. However, some studies have found empirical evidence that restricting systematic reviews of noncomplementary medicine intervention to English-language studies has little effect on the conclusions.104,105 We also included a systematic review that included Chinese–language results from head-to-head trials of pegylated interferon versus nonpegylated interferon, which did not affect conclusions.77 We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies for each Key Question and differences in study design, populations, and outcomes assessed. Evidence from placebo-controlled and head-to-head trials of first-line antiviral therapies (entecavir, tenofovir, and pegylated interferon alfa-2a) was limited, particularly for clinical outcomes, making it difficult to evaluate effectiveness of currently utilized treatments. We included observational studies to evaluate the association between improvement in intermediate outcomes following antiviral therapy and subsequent clinical outcomes, as it is not possible to randomize patients' response to therapy. We focused on results from studies that performed statistical adjustment in order to reduce potential effects from confounding. Another limitation is that we included studies conducted in countries where the prevalence, characteristics (e.g., likelihood of HBeAg-negative chronic HBV infection), and natural history of HBV infection differ from those in the United States, since evidence from settings more applicable to U.S. practice was limited. Including such evidence potentially limits the applicability of the reviewed evidence to screening in the United States.

We also did not include evidence on the effectiveness of surveillance for hepatocellular carcinoma in patients with HBV infection. However, the only two randomized trials were conducted in Asia and reported somewhat mixed results, with one trial showing a 37-percent reduction in hepatocellular carcinoma–related mortality and the other showing no effect of surveillance on overall mortality.106,107

## Emerging Issues

Symptomatic acute HBV infections in the United States have declined approximately 85 percent from the early 1990s to 2009 following the adoption of universal infant vaccination and catch-up vaccinations for children and adolescents.108,109 Substantial reductions in prevalence have been observed among U.S. adolescents and younger adults (up to 50 years of age).109 In addition, universal HBV vaccination has been adopted in over 190 countries24 and epidemiological data indicate declining HBV prevalence globally.110 These trends have important potential implications for future assessments of benefits and harms of HBV screening.

Antiviral therapies for chronic HBV infection continue to evolve.111 Among currently approved drugs for treatment of HBV infection, entecavir and tenofovir have potent antiviral activity, appear to have low rates of drug resistance, and are better tolerated than pegylated interferon alfa-2a, but data on their effects on clinical outcomes are extremely limited.112 Although a number of combination antiviral therapies have been evaluated for management of HBV infection, none has clearly been shown to be superior to monotherapy for achieving intermediate or clinical outcomes and avoiding drug resistance.113 However, research on combination therapies and new investigational agents, including drugs with novel viral targets,112,114 is ongoing.

## Relevance for Priority Populations

HBV infection is more prevalent in the United States among persons originating from countries with high prevalence,115 such as most of Asia and the western Pacific. Black persons are also at higher risk of HBV infection.11 Although the prevalence of HBV infection has declined in adolescents and young adults, data from the 2006 National Health and Nutrition Examination Survey indicated little change in prevalence among adults age 50 years or older.109

## Future Research

Important research gaps limit full understanding of the benefits and harms of screening for HBV infection. Studies that compare clinical outcomes in patients screened and not screened for HBV infection would provide the most direct evidence but would require large sample sizes and long duration of followup. Studies would not necessarily need to be prospective, as well-conducted retrospective studies could also be informative. In lieu of direct evidence on effects of screening on clinical outcomes, studies that prospectively evaluate the accuracy and efficiency of alternative screening strategies (such as strategies targeting persons originating from high-prevalence countries)116 might help identify efficient screening strategies.

More research is also needed on the long-term clinical outcomes associated with use of currently recommended first-line antiviral therapies for chronic HBV infection. Studies evaluating whether antiviral therapy is associated with decreased risk of transmission (as has been shown in the case of HIV infection117) would be useful for identifying additional public health benefits of screening and subsequent treatment. Evidence from observational studies on the association between achieving intermediate outcomes (such as viral clearance or disappearance of HBeAg) and clinical outcomes would be greatly strengthened by improved standardization of the intermediate and clinical outcomes evaluated, and should be designed and analyzed to account for important confounders.118

## Conclusions

Although screening tests can accurately identify adolescents and adults with chronic HBV infection, more research is needed to understand the effects of screening and subsequent interventions on clinical outcomes and to identify optimal screening strategies. The declining incidence and prevalence of HBV infection as a result of universal vaccination programs is likely to impact future assessments of the benefits and harms of HBV screening.