# Results

## Key Question 1 What Are the Benefits of Screening for HBV Versus No Screening in Asymptomatic, Nonpregnant Adolescents and Adults on Morbidity, Mortality, and Disease Transmission?

No study compared clinical outcomes between individuals screened and not screened for HBV infection.

## Key Question 2 What Are the Harms of Screening for HBV Infection (e.g., Labeling, Anxiety, and Harms of Confirmatory Tests, Including Biopsy)?

No study compared harms between individuals screened and not screened for HBV infection.

## Key Question 3 How Well Do Different Screening Strategies Identify Individuals With HBV Infection (e.g., Strategies That Target Persons From High-Prevalence Countries, Men Who Have Sex With Men, Injection Drug Users, Immunization History, or Other Risk Factors)?

### Summary

One fair-quality (n=6,194) cross-sectional study found screening targeted at persons born in countries with higher (≥2%) chronic HBV prevalence, men, and unemployed persons identified 98 percent (48/49) of infections while testing about two-thirds of the population, for a number needed to screen to identify one case of HBV infection of 82. Screening strategies that targeted persons born in higher prevalence countries but focused on behavioral risk factors rather than male sex and employment status resulted in higher proportions of patients tested but lower sensitivities. Screening only patients born in higher prevalence countries would have resulted in testing of 12 percent of patients, a sensitivity of 31 percent, and a number needed to screen to identify one case of HBV infection of 16.

### Evidence

One cross-sectional study provided data to calculate the diagnostic accuracy and yield of alternative HBV screening criteria (Table 2 and Appendixes B1 and B2).35 It evaluated patients attending a French STD clinic and applied alternative screening criteria retrospectively. Of the 7,692 patients evaluated at the clinic during the study period, 6,194 (81%) were screened for HBV infection. Patients were primarily young adults (62% between age 20 and 29 years). Injection drug use was reported in 0.7 percent of patients, and 7.2 percent were born in a high-endemic area (defined as chronic HBV prevalence of ≥8%). Independent predictors of HBV infection in this cohort were medium (prevalence ≥2% to <8%) or high prevalence of HBV in birth country (adjusted odds ratio [OR], 15.8; 95% confidence interval [CI], 5.6 to 44, and OR, 44; 95% CI, 19 to 101, respectively, vs. low-prevalence country), male sex (adjusted OR, 2.4; 95% CI, 1.1 to 5.2), being unemployed (adjusted OR, 3.2; 95% CI, 1.6 to 6.1 vs. student), and unvaccinated status (adjusted OR, 2.9; 95% CI, 1.1 to 7.9 vs. vaccinated status). No cases of HBV infection were found in patients reporting injection drug use, although the sample was small.

Table 2 Alternative Screening Strategies: Study Characteristics

Author, Year Country | Study Design | Sample Size | Setting Population Characteristics | HBV Screening Strategies | Quality
Spenatto, 2013^35^ France | Cross-sectional | N=6,194^*^ | STD clinic Age 20-29 years: 62% Female: 56% Self-reported injection drug use: 0.7% High-endemic area (prevalence ≥8%) country of birth: 7.2% | A: Screen all B: Screen those born in moderate- or high-prevalence (≥2%) country C: Same as B plus men and unemployed D: Screen those born in moderate- or high-prevalence country, or with transfusion history or blood contacts, tattoos, body piercing, more than 2 sexual partners during the last year, hepatitis among sexual partners or household members, or intravenous or intranasal drug use; no screening for patients who reported prior HBV vaccination E: Same as D except prior vaccination history not considered | Fair

* 183 patients (1 HBV case) did not have information on country of birth.

Abbreviations: HBV = hepatitis B virus; STD = sexually transmitted disease.

The prevalence of HBV infection (based on presence of HBsAg) in the sample was 0.8 percent (49/6,194). Using a strategy of screening all patients, 126 persons would need to be screened to identify one case of HBV infection (Table 3). A strategy of screening only patients born in moderate- or high-prevalence countries (≥2% prevalence of chronic HBV infection) would have resulted in 13 percent (761/6,011) persons being screened, a sensitivity of 31 percent (15/48) for identifying patients with HBV infection, and a number needed to screen of 16. Also screening men and unemployed persons would have resulted in 64 percent (3,949/6,194) of the population being screened, a sensitivity of 98 percent (48/49), and a number needed to screen to identify one case of HBV infection of 82. The area under the receiver operating curve (AUROC) for this strategy was 0.92, indicating excellent discrimination. Strategies that included screening based on risk behaviors rather than employment history or being male were associated with higher proportions of patients screened, no increase in sensitivity, and numbers needed to screen similar to those for screening of the entire sample.

Table 3 Effects of Applying Alternative Screening Criteria on Sensitivity and Number Needed to Screen to Identify One Case of Hepatitis B Virus Infection

Author, Year Country | HBV Prevalence | Screening Strategy | Proportion Screened | Sensitivity | Specificity | Number Needed to Screen to Identify 1 Case of HBV Infection
Spenatto, 2013^35^ France | 0.8% (49/6,194) | A: Screen all B: Screen those born in moderate- or high-prevalence (≥2%) country C: Same as B plus men and unemployed D: Screen those born in moderate- or high-prevalence country, or with transfusion history or blood contacts, tattoos, body piercing, more than 2 sexual partners during the last year, hepatitis among sexual partners or household members, or intravenous or intranasal drug use; no screening for patients who reported prior HBV vaccination E: Same as D except prior vaccination history not considered | A: 100% (6,194/6,194) B: 12% (761/6,011) C: 64% (3,949/6,194) D: 73% (4,504/6,194) E: 84% (5,205/6,194) | A: 100% (49/49) B: 31% (15/48) C: 98% (48/49) D: 84% (41/49) E: 94% (46/49) | A: 0% (0/6,145) B: 87% (5,217/5,963) C: 37% (2,244/6,145) D: 27% (1,682/6,145) E: 16% (986/6,145) | A: 126 B: 16 C: 82 D: 110 E: 113

Abbreviation: HBV = hepatitis B virus.

## Key Question 4 In Nonpregnant Adolescents and Adults With No Evidence of HBV Immunity on Screening, How Effective Is HBV Vaccination for Improving Clinical Outcomes?

### Summary

Vaccination is associated with decreased risk of HBV acquisition in health care workers (4 trials; relative risk [RR], 0.5; 95% CI, 0.4 to 0.7) and men who have sex with men (4 trials; RR, 0.2; 95% CI, 0.1 to 0.4) based on serologic markers. Studies were not designed to evaluate the effectiveness of HBV vaccination on long-term clinical outcomes.

### Evidence

A recent systematic review found HBV vaccination in health care workers associated with decreased incidence of HBV acquisition based on serologic markers (appearance of HBsAg or anti-HBc) in four trials (RR, 0.5; 95% CI, 0.4 to 0.7; I^2^=18%).36 Pooled results from one other good-quality37 and two fair-quality trials38,39 of HBV vaccination in men who have sex with men found vaccination strongly associated with decreased HBV acquisition versus placebo based on HBsAg seroconversion (RR, 0.2; 95% CI, 0.1 to 0.4; I^2^=45%), development of elevated serum ALT (RR 0.2; 95% CI 0.2 to 0.3; I^2^=2%), or either marker (RR, 0.4; 95% CI, 0.2 to 0.6; I^2^=66%). The risk of serum anti-HBc conversion was also lower in vaccinated patients than in placebo, but the pooled result was not statistically significant (RR, 0.6; 95% CI, 0.3 to 1.4; I^2^=74%).

## Key Question 5 In Nonpregnant Adolescents and Adults With Chronic HBV Infection, How Effective Is Antiviral Treatment at Improving Intermediate Outcomes (Virological or Histological Improvement or Clearance of HBeAg)?

### Summary

Twenty-two trials compared antiviral treatment to placebo or no treatment and reported intermediate outcomes. Antiviral treatment was more effective than placebo or no treatment in achieving HBeAg loss or seroconversion (10 trials; RR, 2.1; 95% CI, 1.6 to 2.9; I^2^=4%), HBsAg loss or seroconversion (12 trials; RR, 2.4; 95% CI, 1.2 to 4.9; I^2^=0%), ALT normalization (12 trials; RR, 2.5; 95% CI, 2.1 to 3.0; I^2^=27%), reduction in HBV DNA (9 trials; RR, 7.2; 95% CI, 3.2 to 16; I^2^=58%), and histological improvement (7 trials; RR, 2.1; 95% CI, 1.8 to 2.6; I^2^=0%). Results were generally consistent when stratified by individual drug, although some stratified estimates were imprecise and not statistically significant. Antiviral therapy was also more effective than placebo or no treatment for some composite intermediate outcomes, such as a reduction in HBV DNA level plus ALT normalization (6 trials; RR, 8.0; 95% CI, 2.0 to 32; I^2^=79%). Results were generally consistent in sensitivity and subgroup analyses.

Although head-to-head comparisons of entecavir, pegylated interferon alfa-2a, and tenofovir versus older antiviral drugs were limited by small numbers of trials, entecavir and pegylated interferon alfa-2a were associated with greater likelihood of achieving some intermediate outcomes (virological improvement, histological improvement) than lamivudine.

### Evidence

#### Antiviral Therapy Versus Placebo or No Treatment

Twenty-two trials of antiviral treatment versus placebo or no treatment reported intermediate health outcomes (Table 4 and Appendix B5). Four trials evaluated adefovir versus placebo,40-43 eight trials interferon alfa-2b injection versus no treatment,44-51 nine trials lamivudine versus placebo,52-60 and one study tenofovir versus placebo.61 No placebo-controlled trial of pegylated interferon alfa-2a or entecavir met inclusion criteria. One trial evaluated telbivudine versus placebo, but it evaluated only continuous outcomes and could not be included in pooled analyses.62 Nine trials40,41,45-47,49,55,58,61 were conducted primarily in the United States or Europe, and the remainder were conducted in other geographic areas, including countries with high HBV prevalence. Fifteen trials enrolled patients who were exclusively or primarily HBeAg-positive.41-44,47-51,55-57,59-61 Two trials restricted inclusion to adolescents41,61 and the rest focused on adults (mean age, 24 to 46 years). The trials predominantly enrolled men (proportion male, 60 to 94%). In 11 trials that reported the proportion of patients with baseline cirrhosis, rates ranged from 5 to 44 percent.40,44-46,48,50,51,54,55,57,58 In trials that did not report the prevalence of baseline cirrhosis, patients with decompensated liver disease were generally excluded.41-43,49,52,56,59-62 Study duration ranged from 8 weeks to 3 years. Twelve trials40-44,47,48,53,57,58,60,61 reported outcomes on antiviral therapy, three trials52,56,59 reported outcomes following discontinuation of antiviral therapy, and seven trials45,46,49-51,54,55 reported both. Two trials were rated good quality,49,61 four trials poor quality,44,45,52,53 and the remainder fair quality (Appendix B6). Common methodological shortcomings were unclear or inadequate methods of randomization, allocation concealment, and blinding.

Table 4 Studies of Antiviral Therapy Versus Placebo or No Treatment Reporting Intermediate Outcomes: Study Characteristics

Author, Year | Study Design, Duration | Country | Population | HBeAg Status | Cirrhosis | Intermediate Outcomes Reported | Quality
Adefovir Vs. Placebo
Hadziyannis,2003^40^ | RCT 48 weeks | Canada, Greece, Israel, France, Italy, Australia, Taiwan, Singapore | n=185 Mean age, 46 years 83% male | Negative | 11% | ALT normalization Virologic improvement Histologic improvement | Fair
Jonas, 2008^41^ | RCT 48 weeks | Germany, Poland, Spain, United Kingdom, United States | n=83 Mean age, 14 years 75% male | Positive | NR | ALT normalization Composite outcomes | Fair
Marcellin, 2003^42^ | RCT 48 weeks | Australia, Canada, France, Germany, Italy, Malaysia, The Philippines, Singapore, Spain, Taiwan, Thailand, United Kingdom, United States^*^ | n=515 Mean age, 35 years 74% male | Positive | NR | HBeAg loss/seroconversion ALT normalization Histologic improvement | Fair
Zeng, 2006^43^ | RCT 12 weeks | China | n=480 Mean age, 32 years 83% male | Positive | NR | HBeAg loss/seroconversion ALT normalization Virologic improvement | Fair
Interferon Alfa-2b Vs. No Treatment
Bayraktar, 1993^44^ | Controlled trial 6 months | Turkey | n=35 Mean age, 36 years 71% male | Positive | 29% | HBeAg loss/seroconversion HBsAg loss/seroconversion ALT normalization | Poor
Hadziyannis, 1990^45^ | RCT 14-16 weeks treatment + 2 year followup | Greece | n=50 Mean age, 49 years 94% male | Negative | 44% | Composite outcomes | Poor
Lampertico, 1997^46^ | Open label RCT 3 years | Italy | n=42 Mean age, 46 years 86% male | Negative | 17% | HBsAg loss/seroconversion Histologic improvement Composite outcomes | Fair
Muller, 1990^47^ | RCT 10 months | Germany | n=58 Mean age NR; range, 18-65 years 79% male | Positive | 5% | Composite outcomes | Fair
Perez, 1990^48^ | RCT 24 weeks (control phase) | Argentina | n=35 Mean age, 39 years 77% male | Positive | 14% | HBeAg loss/seroconversion HBsAg loss/seroconversion ALT normalization Virologic improvement | Fair
Perrillo, 1990^49^ | RCT 10 months | United States | n=169 Mean age, 40 years 85% male | Positive | NR | HBsAg loss/seroconversion Composite outcomes | Good
Sarin, 1996^50^ | RCT 16 months | India | n=41 Mean age, 35 years 94% male | Positive | 44% | HBeAg loss/seroconversion HBsAg loss/seroconversion Virologic improvement Composite outcomes | Fair
Waked. 1990^51^ | RCT 16 months | Egypt | n=40 Mean age, 36 years 78% male | Positive | 40% | HBeAg loss/seroconversion HBsAg loss/seroconversion Histologic improvement | Fair
Lamivudine Vs. Placebo
Ali, 2003^52^ | RCT 12 months | Iraq | n=74 Mean age NR % male NR | Negative | NR | HBsAg loss/seroconversion | Poor
Bozkaya, 2005^53^ | Controlled trial 12 months (control phase) | Turkey | n=55 Mean age, 36 years 60% male | Negative | NR^**^ | ALT normalization | Poor
Chan, 2007^*,54^ | RCT 30 months | China | n=139 Mean age, 39 years 84% male | Negative | 27% | HBsAg loss/seroconversion ALT normalization Virologic improvement Histologic improvement Composite outcomes | Fair
Dienstag, 1999^55^ | RCT 16 months | United States | n=137 Median age, 39 years 83% male | Positive | 10% | HBeAg loss/seroconversion HBsAg loss/seroconversion ALT normalization Virologic improvement Histologic improvement | Fair
Lai, 1997^56^ | RCT 8 weeks | Hong Kong | n=42 Mean age, 32 years 64% male | Positive | NR | HBeAg loss/seroconversion | Fair
Lai, 1998^57^ | RCT 1 year | Hong Kong, Taiwan, Singapore | n=358 Median age, 31 years 73% male | Positive | 5% | ALT normalization Histologic improvement Composite outcomes | Fair
Tassopoulos, 1999^58^ | RCT 24 weeks | Greece | n=125 Median age, 43 years 80% male | Negative | 15% | HBsAg loss/seroconversion Composite outcomes | Fair
Yalcin, 2004^59^ | RCT 1 year | Turkey | n=46 Mean age, 24 years 54% male | Positive | NR | HBeAg loss/seroconversion HBsAg loss/seroconversion Virologic improvement Composite outcomes | Fair
Yao, 1999^60^ | RCT 12 weeks | China | n=429 Mean age, 32 years 73% male | Positive | NR | HBeAg loss/seroconversion ALT normalization Virologic improvement | Fair
Tenofovir Vs. Placebo
Murray, 2012^61^ | RCT 72 weeks | United States, Bulgaria, France, Poland, Romania, Spain, Turkey | n=106 Mean age, 15 years 73% male | Positive | NR | HBeAg loss/seroconversion HBsAg loss/seroconversion ALT normalization Virologic improvement Composite outcomes | Good

* Patient population was 60% Asian.

** 24% had fibrosis.

Abbreviations: ALT = alanine aminotransferase; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; NR = not reported; RCT = randomized, controlled trial.

HBeAg loss or seroconversion. In patients with HBeAg-positive HBV infection, antiviral therapy was more effective than placebo or no treatment for achieving HBeAg loss or seroconversion (10 trials; RR, 2.1; 95% CI, 1.6 to 2.9; I^2^=4%)42-44,48,50,51,55,59-61 (Figure 2). One trial reported no HBeAg loss in either treated or control groups.56 When analyses were stratified by specific antiviral drug, the risk estimate was larger for interferon alfa-2b (5 trials; RR, 3.6; 95% CI, 1.9 to 6.9; I^2^=5%)44,48,50,51 than for lamivudine (3 trials; RR, 1.7; 95% CI, 1.0 to 3.0; I^2^=0%),55,59,60 adefovir (2 trials; RR, 1.8; 95% CI, 0.8 to 4; I^2^=58%),42,43 or tenofovir (1 trial; RR, 1.4; 95% CI, 0.6 to 3.4),61 although estimates were imprecise and based on only one or two trials for drugs other than interferon. The adefovir risk estimate had the most statistical heterogeneity. It was based on two trials: a longer duration trial42 (72 weeks) found adefovir associated with an increased likelihood of HBeAg loss versus placebo (RR, 2.5; 95% CI, 1.5 to 4.2) and a shorter duration trial43 (12 weeks) found no effect (RR, 1.1; 95% CI, 0.5 to 2.7).

Figure 2 HBeAg Loss, Antiviral Therapy Versus Placebo or No Treatment

* 30 mg–group versus placebo.

** 68-week data.

Abbreviations: df = degree of freedom; HBeAG = hepatitis B e antigen; M-H = Mantel-Haenszel.

The risk estimate was similar when restricted to outcomes assessed during antiviral treatment (10 trials; RR, 2.3; 95% CI, 1.6 to 3.1; I^2^=5%).42-44,48,50,51,55,59-61 Stratifying all antiviral trials according to duration resulted in similar estimates for studies 1 year or less in duration (6 trials; RR, 2.0; 95% CI, 1.3 to 3.2; I^2^=27%)42-44,48,59,60 and those of more than 1 year duration (4 trials; RR, 2.1; 95% CI, 1.4 to 3.1; I^2^=0%).50,51,55,61 Removing one poor-quality trial44 also had no effect on the overall estimate (8 trials; RR, 2.1; 95% CI, 1.6 to 2.8; I^2^=0%).42,43,48,50,51,55,60,61

HBsAg loss or seroconversion. Antiviral therapy was more effective than placebo for achieving HBsAg loss (11 trials; RR, 2.4; 95% CI, 1.2 to 4.9; I^2^=0%)44,46,48-52,54,55,58,61 (Figure 3). The pooled estimate was heavily influenced by studies of interferon alfa-2b, which accounted for 24 of the 30 events in patients on antiviral therapy (6 trials; RR, 2.7; 95% CI, 1.1 to 6.4; I^2^=0%).44,46,48-51 The pooled estimate favored lamivudine over placebo, but the difference was not statistically significant (4 trials; RR, 1.7; 95% CI, 0.4 to 7.1; I^2^=0%).52,54,55,58 The estimate for tenofovir was imprecise and based on one trial (RR, 3.1; 95% CI, 0.13 to 75).61

Figure 3 HBsAg Loss, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; HBsAG = hepatitis B surface antigen; M-H = Mantel-Haenszel.

HBsAg loss 5

Estimates were similar for trials of HBeAg-positive patients (7 trials; RR, 2.6; 95% CI, 1.1 to 6.1; I^2^=0%)44,48-51,55,61 and HBeAg-negative patients (4 trials; RR, 1.9; 95% CI, 0.5 to 7.8; I^2^=0%).46,52,54,58 Results were also similar when the analysis was restricted to trials of greater than 1 year duration (7 trials; RR, 2.2; 95% CI, 0.9 to 5.1; I^2^=0%)46,50,51,54,55,58,61 or when excluding two poor-quality44,52 trials (9 trials; RR, 2.2; 95% CI, 1.0 to 5.0; I^2^=0%).46,48-51,54,55,58,61 Restricting the analysis to outcomes that occurred during antiviral therapy resulted in a somewhat attenuated risk estimate (RR, 1.6; 95% CI, 0.7 to 3.9; I^2^=0).44,48,50,51,55,58,61

ALT normalization. Antiviral therapy was more effective than placebo for achieving normalization of ALT levels (12 trials; RR, 2.5; 95%, CI, 2.1 to 3.0; I^2^=27%)38-42,46,51-53,55,58,59 (Figure 4). Estimates were similar for adefovir (4 trials; RR, 2.9; 95% CI, 2.3 to 3.6; I^2^=0%),40-43 lamivudine (5 trials; RR, 2.4; 95% CI, 1.6 to 3.6; I^2^=54%),53-55,57,60 and tenofovir (1 trial; RR, 2.0; 95% CI, 1.4 to 2.9).61 The estimate for interferon alfa-2b was imprecise (2 trials; RR, 5.0; 95% CI, 0.6 to 40; I^2^=28%).44,48 Although statistical heterogeneity was present in trials of lamivudine, all trials favored antiviral therapy (range of RR estimates, 1.6 to 5.6).

Figure 4 ALT Normalization, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: ALT = alanine aminotransferase; df = degree of freedom; M-H = Mantel-Haenszel.

ALT normalization

Results were similar for HBeAg-positive patients (9 trials; RR, 2.7; 95% CI, 2.2 to 3.3; I^2^=11%)41-44,48,55,57,60,61 and HBeAg-negative patients (3 trials; RR, 2.0; 95% CI, 1.4 to 2.9; I^2^=26%),40,53,54 for studies of more than 1 year duration (5 trials; RR, 2.4; 95% CI, 1.6 to 3.5; I^2^=57%),48,54,55,57,61 or after excluding two poor-quality44,53 studies (10 trials; RR, 2.5; 95% CI, 2.0 to 3.0; I^2^=31%).40-43,48,54,55,57,60,61 The risk estimate was similar when the analysis was restricted to outcomes that occurred during antiviral treatment (12 trials; RR, 2.5; 95% CI, 2.2 to 3.0; I^2^=0%).38-42,46,51-53,55,58,59

Virological improvement. Antiviral therapy was more effective than placebo or no treatment for achieving a reduction in HBV DNA level (9 trials; RR, 7.2; 95% CI, 3.2 to 16; I^2^=58%)40,43,48,50,54,55,59-61 (Figure 5). When results were stratified by individual antiviral drug, the estimate for lamivudine was the most precise (4 trials; RR, 4.4; 95% CI, 2.2 to 8.6; I^2^=46%).54,55,59,60 Although statistical heterogeneity was present, estimates from all trials favored lamivudine (range of RR estimates, 2.5 to 7.0). For adefovir (2 trials; RR, 29; 95% CI, 4.0 to 204; I^2^=0%),40,43 interferon alfa-2b (2 trials; RR, 7.5; 95% CI, 1.4 to 40; I^2^=0%),48,50 and tenofovir (1 trial; RR, 97; 95% CI, 6.1 to 1,526),61 analyses were based on one or two trials with a total of no events or one event in the placebo or no-treatment groups, resulting in very imprecise estimates.

Figure 5 HBV DNA Loss, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; HBV = hepatitis B virus; M-H = Mantel-Haenszel.

HBV DNA loss 5

Limiting the analysis to outcomes that occurred during antiviral therapy (9 trials; RR, 8.6; 95% CI, 3.8 to 20; I^2^=64%)40,43,48,50,54,55,59-61 or to studies of more than 1 year duration (4 trials; RR, 8.4; 95% CI, 1.5 to 49; I^2^=76%)50,54,55,61 resulted in similar estimates, as did limiting the analysis to studies that enrolled HBeAg-positive patients (7 trials; RR, 6.2; 95% CI, 2.7 to 14; I^2^=56%).43,48,50,55,59-61 HBeAg-negative patients were enrolled in two trials, both of which reported statistically significant, but very imprecise, risk estimates favoring antiviral therapy (RR, 64; 95% CI, 4.0 to 1,009,40 and RR, 4.8; 95% CI, 0.62 to 36^54^). None of the trials was rated poor quality.

Histological improvement. Antiviral therapy was more effective than placebo or no treatment at improving histological outcomes (7 trials; RR, 2.1; 95% CI, 1.8 to 2.6; I^2^=0%)40,42,46,51,54,55,57 (Figure 6). The definition of histological improvement varied among the studies, although many used a reduction of two or more points in Histology Activity Index (HAI) scores (Appendix B5). When stratified by individual drug, estimates were similar for adefovir (2 trials; RR, 1.9; 95% CI, 1.3 to 2.8,^40^ and RR, 2.1; 95% CI, 1.5 to 2.8^42^) and lamivudine (3 trials; RR, 2.3; 95% CI, 1.7 to 3.2; I^2^=0%).54,55,57 Estimates from trials of interferon alfa-2b were less precise but consistent with those for the other drugs (2 trials; RR, 3.5; 95% CI, 0.8 to 15,46 and RR, 4.0; 95% CI, 0.5 to 33^51^).

Figure 6 Histologic Improvement, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel Haenszel.

Histologic improvement

Estimates were similar when the analysis was restricted to studies of more than 1 year duration (5 trials; RR, 2.4; 95% CI, 1.8 to 3.2; I^2^=0%)46,51,54,55,57 or when results were stratified for HBeAg-positive patients (4 trials; RR, 2.2; 95% CI, 1.8 to 2.7; I^2^=0%)42,51,55,57 and HBeAg negative patients (3 trials; RR, 2.1; 95% CI, 1.4 to 3; I^2^=0%).40,46,54 No trial was rated poor quality.

Composite intermediate outcomes. Composite intermediate outcomes were reported in 10 trials (Table 5).45-47,49,50,54,57,58,61,63 The most commonly reported composite outcome was loss of HBV DNA plus ALT normalization (6 trials; RR, 8.0; 95% CI, 2.0 to 32; I^2^=79%)45,46,54,58,61,63 (Figure 7). Estimates from all trials favored antiviral therapy (range of RR estimates, 4.0 to 78), although some estimates were very imprecise and findings did not always reach statistical significance.

Table 5 Studies of Antiviral Therapy Versus Placebo or No Treatment Reporting Composite Outcomes

Author, Year | Results | Quality
Adefovir Vs. Placebo
Jonas, 2008^63^ | HBV DNA <1000 copies/mL + ALT normalization: 13/56 (23%) vs. 0/27 (0%); RR, 13; 95% CI, 0.8 to 215 | Fair
Interferon Alfa-2b Vs. No Treatment
Hadziyannis, 1990^45^ | HBV DNA undetectable + ALT normalization: 11/25 (44%) vs. 2/25 (8%); RR, 5.5; 95% CI, 1.4 to 22 HBV DNA + ALT reduced by >50% from baseline: 3/25 (12%) vs. 6/25 (24%); RR, 0.5; 95% CI, 0.1 to 1.8 | Poor
Lampertico, 1997^46^ | Loss of HBV DNA + ALT normalization: 6/21 (29%) vs. 0/21 (0%); RR, 13; 95% CI, 0.8 to 217 Loss of HBsAg +/or HBV DNA: 7/21 (33%) vs. 0/21 (0%); RR, 15; 95% CI, 0.9 to 247 | Fair
Muller, 1990^47^ | Loss of HBsAg, HBeAg, HBV DNA + ALT normalization: 1/30 (3%) vs. 0/28 (0%); RR, 2.8; 95% CI, 0.1 to 66 Loss of HBeAg, HBV DNA + ALT normalization : 8/30 (27%) vs. 0/28 (0%); RR, 15; 95% CI, 0.9 to 248 | Fair
Perrillo, 1990^48^ | Loss of HBeAg + HBV DNA: 38/126 (26%) vs. 3/43 (7%); RR, 4.6; 95% CI, 1.5 to 14 | Good
Sarin, 1996^50^ | Loss of HBeAg + HBV DNA: 10/20 (50%) vs. 1/21 (5%); RR, 11; 95% CI, 1.5 to 75 | Fair
Lamivudine Vs. Placebo
Lai, 1998^57^ | HBeAg seroconversion + HBV DNA undetectable: 39/275 (14%) vs. 3/70 (4%); RR, 3.31; 95% CI, 1.05 to 10.40 | Fair
Chan, 2007^54^ | HBV DNA <10,000 copies/ml + ALT normalization at 24 months (time on treatment): 50/89 (56%) vs. 5/47 (11%); reported adjusted OR,^*^ 11; 95% CI, 3.8 to 30; RR, 5.3; 95% CI, 2.3 to 12 HBV DNA <10,000 copies/ml + ALT normalization at 30 months (6 months after treatment cessation): 23/89 (26%) vs. 9/47 (19%); RR, 1.3; 95% CI, 0.7 to 2.7 | Fair
Tassopoulos, 1999^58^ | HBV DNA <2.5 pg/mL + ALT normalization: 34/54 (63%) vs. 3/54 (6%); RR, 11; 95% CI, 3.7 to 35 | Fair
Yalcin, 2004^59^ | HBeAg seroconversion + HBV DNA loss: 1/13 (8%) vs. 1/33 (3%); RR, 2.5; 95% CI, 0.17 to 38 | Fair
Tenofovir Vs. Placebo
Murray, 2012^61^ | HBV DNA <400 copies/mL + ALT normalization: 37/52 (71%) vs. 0/54 (0%); RR, 77; 95% CI, 5 to 1,235 HBV DNA <400 copies/mL + ALT normalization + HBeAg loss: 11/52 (21%) vs. 0/54 (0%); RR, 24; 95% CI, 1.4 to 395 HBV DNA <400 copies/mL + ALT normalization + HBsAg loss: 8/52 (15%) vs. 0/54 (0%); RR, 18; 95% CI, 1.0 to 298 | Good

* OR adjusted for baseline ALT and HBV DNA.

Note: Statistically significant results appear in bold type.

Abbreviations: ALT = alanine aminotransferase; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; OR = odds ratio; RR = relative risk.

Figure 7 HBV DNA Loss Plus ALT Normalization, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: ALT = alanine aminotransferase; df = degree of freedom; HBV = hepatitis B virus; M-H = Mantel-Haenszel.

Results were similar when analyses were restricted to outcomes that occurred during antiviral therapy (6 trials; RR, 8.3; 95% CI, 4.1 to 17; I^2^=21%).45,46,54,58,61,63 Two trials of HBeAg-positive patients reported no events in the control groups, resulting in highly imprecise risk estimates (RR, 13; 95% CI, 0.8 to 215,63 and RR, 78; 95% CI, 4.9 to 1,236^61^). The risk estimate remained statistically significant when the analysis was restricted to HBeAg-negative patients (4 trials; RR, 4.8; 95% CI, 1.3 to 19; I^2^=78%)45,46,54,58 or after excluding one poor-quality trial (RR, 9.3; 95% CI, 1.6 to 55; I^2^=83%).45 Results were also similar, but imprecise, for trials with followup duration of more than 1 year (3 trials; RR, 9.6; 95% CI, 0.3 to 331; I^2^=88%).46,54,61

The composite intermediate outcome of clearance of HBeAg plus suppression of HBV DNA was evaluated in four trials.49,50,57,59 Interferon alfa-2b was more effective than no treatment for achieving this outcome in two trials (RR, 4.6; 95% CI, 1.5 to 14,49 and RR, 11; 95% CI, 1.5 to 75^50^), and lamivudine was more effective than placebo in one larger (n=358) trial (RR, 3.3; 95% CI, 1.1 to 10)57 but not in another smaller (n=42) trial (RR, 2.5; 95% CI, 0.17 to 38).59 One other trial found tenofovir more effective than placebo for achieving virological clearance, normalization of AST level, plus loss of HBeAg (RR, 24; 95% CI, 1.4 to 395).61

#### Entecavir, Pegylated Interferon, or Tenofovir Versus Adefovir, Nonpegylated Interferon, Lamivudine, Or Telbivudine

Four trials (in 6 publications) compared entecavir versus lamivudine,64-69 two trials compared pegylated interferon alfa-2a versus lamivudine,70,71 and two trials (reported in 1 publication)72 compared tenofovir versus adefovir (Appendix B5). Duration of followup ranged from 48 to 96 weeks. Five trials predominantly enrolled HBeAg-positive patients (78 to 100%),64-66,68-70,72 and the remaining three trials67,71,72 enrolled almost exclusively HBeAg-negative patients (99 to 100%). All of the trials enrolled patients with compensated liver disease. Four studies were rated good quality64,67,70,71 and the other four were rated fair quality, primarily due to inadequate or unclear blinding (Appendix B6).

All head-to-head comparisons were limited by small numbers of trials (1 to 4) (Table 6). Compared with lamivudine, entecavir was associated with increased likelihood of virological improvement (4 trials; RR, 1.6; 95% CI, 1.1 to 2.5; I^2^=94%)64,67-69 and histological improvement (2 trials; RR, 1.2; 95% CI, 1.1 to 1.3; I^2^=0%),64,67 and pegylated interferon alfa-2b with increased likelihood of HBeAg loss or seroconversion (1 trial; RR, 1.6; 95% CI, 1.2 to 2.1),70 HBsAg loss or seroconversion (2 trials; RR, 16; 95% CI, 2.2 to 121; I^2^=0%),70,71 ALT normalization (2 trials; RR, 1.4; 95% CI, 1.2 to 1.6; I^2^=0),70,71 virological improvement (2 trials; RR, 2.8; 95% CI, 1.9 to 4.4; I^2^=0%),70,71 and histological improvement (2 trials; RR, 1.2; 95% CI, 1.0 to 1.4; I^2^=0%).70,71 Results for entecavir versus lamivudine on virological response were characterized by marked heterogeneity (4 trials; RR, 1.6; 95% CI, 1.1 to 2.5; I^2^=94%)64,67-69 (Figure 8). There were no clear differences between tenofovir and adefovir on various intermediate outcomes, in part due to imprecise estimates.72 There were too few studies to conduct meaningful sensitivity or stratified analyses.

Table 6 Head-to-Head Studies of Antiviral Therapy Reporting Intermediate Outcomes

Outcome | Entecavir Vs. Lamivudine | Pegylated Interferon Alfa-2a Vs. Lamivudine | Tenofovir Vs. Adefovir
HBeAg loss/seroconversion | RR, 1.2 (95% CI, 0.9 to 1.5; I^2^=0%); 3 trials64,68,69 | RR, 1.6 (95% CI, 1.2 to 2.1); 1 trial70 | RR, 1.2 (95% CI, 0.7 to 2.1); 1 trial72
HBsAg loss/seroconversion | RR, 1.8 (95% CI, 0.9 to 3.9); 1 trial64 | RR, 16 (95% CI, 2.2 to 121; I^2^=0%); 2 trials70,71 | RR, 5.7 (95% CI, 0.3 to 103); 1 trial72
ALT normalization | RR, 1.1 (95% CI, 1.0 to 1.2; I^2^=0%); 4 trials64,67-69 | RR, 1.4 (95% CI, 1.2 to 1.6; I^2^=0%); 2 trials70,71 | RR, 1.1 (95% CI, 0.9 to 1.4; I^2^=73%); 2 trials72
Virological improvement | RR, 1.6 (95% CI, 1.1 to 2.5; I^2^=94%); 4 trials64,67-69 | RR, 2.8 (95% CI, 1.9 to 4.4; I^2^=0%); 2 trials70,71 | RR, 2.9 (95% CI, 0.6 to 15; I^2^=97%); 2 trials72
Histologic improvement | RR, 1.2 (95% CI, 1.1 to 1.3; I^2^=0%); 2 trials64,67 | RR, 1.2 (95% CI, 1.0 to 1.4; I^2^=0%); 2 trials70,71 | RR, 1.1 (95% CI, 1.0 to 1.2; I^2^=0%); 2 trials72

Note: Statistically significant results appear in bold type

Abbreviations: ALT = alanine aminotransferase; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; RR = relative risk.

Figure 8 HBV DNA Loss, Head-to-Head Studies of Antiviral Therapy

Abbreviations: df = degree of freedom; HBV = hepatitis B virus; M-H = Mantel-Haenszel.

## Key Question 6 In Nonpregnant Adolescents and Adults With Chronic HBV Infection, How Effective Is Antiviral Treatment at Improving Health Outcomes?

### Summary

Based on primarily fair-quality randomized trials of antiviral therapy versus placebo or no treatment, pooled estimates for incident cirrhosis (3 trials; RR, 0.70; 95% CI, 0.33 to 1.46; I^2^=0%), hepatocellular carcinoma (5 trials; RR, 0.57; 95% CI, 0.32 to 1.04; I^2^=2%), and mortality (5 trials; RR, 0.55; 95% CI, 0.18 to 1.71; I^2^=43%) all favored antiviral therapy over placebo. None of the differences was statistically significant, estimates were imprecise due to small numbers of events, and some trials had relatively short duration of followup. One study found that disease worsening was more likely in placebo patients than those treated with lamivudine (adjusted hazard ratio [HR], 0.5; 95% CI, 0.6 to 0.7). There were too few clinical events in head-to-head trials of entecavir or pegylated interferon alfa-2a versus lamivudine and pegylated versus nonpegylated interferon to determine effects on clinical outcomes.

### Evidence

#### Antiviral Therapy Versus Placebo or No Treatment

Eleven randomized, controlled trials (RCTs) of antiviral therapy versus placebo or no treatment for chronic HBV infection reported incident cirrhosis, hepatocellular carcinoma, or mortality (Table 7 and Appendix B5).41,43,46,49,51,54,55,57,73,75,76 Three trials evaluated interferon alfa-2b,46,49,51 two trials interferon alfa-2a,73,75 two trials adefovir,41,43 and four trials lamivudine.54,55,57,76 One trial was rated good quality49 and the remainder fair quality41,43,46,51,54,55,57,73,75,76 (Appendix B6). Methodological shortcomings in the fair-quality trials included inadequate details about method of randomization and/or allocation concealment and blinding. Sample sizes ranged from 40 to 651 patients, and duration of followup ranged from 10 months to 7.5 years.

Table 7 Studies of Antiviral Therapy Versus Placebo or No Treatment Reporting Health Outcomes

Author, Year | Study Design Duration | Country | Population | HBeAg Status | Cirrhosis | Health Outcomes | Quality
Adefovir Vs. Placebo
Jonas, 2008^41^ | RCT 11 months | Germany, Poland, Spain, United Kingdom, United States | n=83 Mean age, 15 years 75% male | Positive | NR | Mortality | Fair
Zeng, 2006^43^ | RCT 12 weeks | China | n=480 Mean age, 32 years 83% male | Positive | NR | Mortality | Fair
Interferon Alfa-2a Vs. Placebo
Lin, 1999^73^ Methods: Liaw, 1994^74^ | RCT 4 months + mean 7 years followup | Taiwan | n=101 Mean age, 32 years 100% male | Positive | 12% | Incident cirrhosis Hepatocellular cancer Mortality | Fair
Mazella, 1999^75^ | RCT 6 months + 7 years followup | Italy | n=64 Mean age, 38 years 78% male | Positive | N/A^*^ | Incident cirrhosis Hepatocellular cancer Mortality | Fair
Interferon Alfa-2b Vs. No Treatment
Lampertico, 1997^46^ | Open label RCT 2 years + 1 year followup | Italy | n=42 Mean age, 46 years 86% male | Negative | 17% | Hepatocellular cancer | Fair
Perrillo, 1990^49^ | RCT 16 weeks + 6 months followup | United States | n=169 Mean age, 40 years 85% male | Positive | NR | Mortality | Good
Waked, 1990^51^ | RCT 16 weeks + 1 year followup | Egypt | n=40 Mean age, 36 years 78% male | Positive | 40% | Incident cirrhosis Mortality | Fair
Lamivudine Vs. Placebo
Chan, 2007^54^ | RCT 2 years + 6 months followup | China | n=139 Mean age, 39 years 84% male | Negative | 27% | Hepatocellular cancer | Fair
Dienstag, 1999^55^ | RCT 1 year + 16 weeks followup | United States | n=137 Median age, 39 years 83% male | Positive | 10% | Mortality | Fair
Lai, 1998^57^ | RCT 1 year | Hong Kong, Taiwan, Singapore | n=358 Median age, 31 years 73% male | Positive | 5% | Mortality | Fair
Liaw, 2004^76^ | RCT Median 2.7 years | Australia, Hong Kong, New Zealand, Singapore, Taiwan, Thailand | n=651 Median age, 43 years 85% male | Positive | 33% | Disease severity^**^ Hepatocellular cancer Mortality | Fair

* People with cirrhosis excluded from study.

** Based on Child-Pugh score, separately and in combination with spontaneous bacterial peritonitis with sepsis, renal insufficiency, bleeding gastric or esophageal varices, development of hepatocellular carcinoma, or death related to liver disease.

Abbreviations: HBeAg = hepatitis B e antigen; N/A = not applicable; NR = not reported; RCT = randomized, controlled trial.

The largest trials evaluated lamivudine57,76 and adefovir.43 One of the lamivudine trials followed patients for 1 year57 and the other for a median of 32 months.76 The placebo-controlled phase of the adefovir trial was 12 weeks.43 The two longest duration trials followed patients for 7 years after completing 18 weeks or 6 months of interferon alfa-2a therapy.73,75 Five trials were conducted in the United States and/or European countries, and the remaining six trials were conducted in Asia or the Middle East. Most study participants were HBeAg-positive at baseline; one trial of interferon alfa-2b46 and one trial of lamivudine54 enrolled primarily HBeAg-negative patients. The proportion of patients with cirrhosis at baseline ranged from 5 to 40 percent in seven studies (median, 17%). Four studies excluded patients with decompensated liver disease41,43,49 or cirrhosis.75 One study enrolled adolescents.41

Analyses of clinical outcomes were limited by the small numbers of events. There were a total of 26 cases of incident cirrhosis, 47 cases of hepatocellular carcinoma, and 31 deaths. Among trials that reported mortality, two trials of adefovir41,43 and two trials of lamivudine55,57 recorded no deaths. Although pooled estimates for incident cirrhosis (3 trials; RR, 0.70; 95% CI, 0.33 to 1.46; I^2^=0%)51,73,75 (Figure 9), hepatocellular carcinoma (5 trials; RR, 0.57; 95% CI, 0.32 to 1.04; I^2^=2%)46,54,73,75,76 (Figure 10), and mortality (5 trials; RR, 0.55; 95% CI, 0.18 to 1.71; I^2^=43%)49,51,73,75,76 (Figure 11) all favored antiviral therapy over placebo, none of the differences was statistically significant. Excluding trials with less than 2 years of followup46,54,73,75,76 resulted in similar trends, but with less precise estimates.

Figure 9 Incident Cirrhosis, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

Incident cirrhosis

Figure 10 Hepatocellular Cancer, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

HCC

Figure 11 Mortality, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

Mortality

The pooled estimate for hepatocellular carcinoma nearly reached statistical significance and was heavily influenced by results from the largest trial (n=651), which enrolled Asian patients with more advanced liver disease and reported about 70 percent (33/47) of cases in the pooled analysis.76 This trial was discontinued early (median followup, 2.7 years) after reaching a prespecified stopping threshold on a composite primary outcome (hepatic decompensation, hepatocellular carcinoma, spontaneous bacterial peritonitis, bleeding gastroesophageal varices, or liver-related mortality). For hepatocellular cancer, it reported an RR for lamivudine versus placebo of 0.52 (95% CI, 0.27 to 1.02), which was similar to the pooled estimate. When adjusted for country, sex, baseline ALT, Child-Pugh score, and Ishak fibrosis score, the estimate from this trial was statistically significant (adjusted HR, 0.49; 95% CI, 0.25 to 0.99).

Adjusted HRs in one fair-quality trial of lamivudine versus placebo found that worsening of liver disease, measured by an increase in Child-Pugh scores, was more likely in patients receiving placebo (adjusted HR, 0.5; 95% CI, 0.2 to 0.9); results for disease progression, which included Child-Pugh score increase and serious health outcomes (see footnote to Table 7), were similar (adjusted HR, 0.5; 95% CI, 0.6 to 0.7).76

No trial reported outcomes related to long-term quality of life.

#### Entecavir, Pegylated Interferon Alfa-2a, or Tenofovir Versus Adefovir, Interferon Alfa-2b, Lamivudine, or Telbivudine

Four large head-to-head trials of entecavir or pegylated interferon alfa-2a versus lamivudine reported rates of hepatocellular cancer or mortality (Appendixes B5 and B6).64-67,70,71 All trials were rated good quality.

The two trials of entecavir versus lamivudine were of similar design, except that one enrolled HBeAg-positive patients64-66 and the other HBeAg-negative patients.67 Baseline rates of cirrhosis were 2 percent in both studies and duration of followup was up to 96 weeks. The incidence of clinical events was low, resulting in imprecise estimates for risk of hepatocellular cancer (2 events; RR 3.0; 95% CI, 0.31 to 28; I^2^=0%) and mortality (4 events; RR, 1.1; 95% CI, 0.1 to 9.1; I^2^=40%). The two trials70,71 of pegylated interferon alfa-2a versus lamivudine reported no cases of hepatocellular cancer and only two deaths (RR, 1.0; 95% CI, 0.1 to 9.7; I^2^=0%). Duration of followup was 72 weeks in both studies; one study70 enrolled HBeAg-positive patients and the other71 enrolled HBeAg-negative patients. Pooling results from all four trials for mortality also showed no statistically significant difference between entecavir or pegylated interferon alfa-2a and lamivudine, with a somewhat more precise estimate (RR, 0.9; 95% CI, 0.3 to 3.1; I^2^=0%).

We identified no English-language trials of pegylated vs. nonpegylated interferon. One good-quality systematic review included nine Chinese-language trials of pegylated versus nonpegylated interferon, but no deaths were reported in the trials.77

## Key Question 7 In Nonpregnant Adolescents and Adults With Chronic HBV Infection, How Effective Is Education or Behavior Change Counseling in Reducing Transmission and Improving Health Outcomes?

We identified no trials on the effectiveness of education or behavior change counseling in patients with chronic HBV infection for reducing transmission or improving health outcomes.

## Key Question 8 What Are the Harms Associated With Antiviral Treatment for HBV Infection?

### Summary

There were no statistically significant differences between antiviral therapy and placebo or no treatment in risk for serious adverse effects (12 trials; RR, 0.8; 95% CI, 0.6 to 1.1; I^2^=0%) or any adverse events (7 trials; RR, 0.96; 95% CI, 0.9 to 1.0; I^2^=0%). Antiviral therapy was associated with more withdrawals due to adverse effects than placebo or no treatment (9 trials; RR, 3.97; 95% CI, 1.4 to 11; I^2^=0%). Results were largely consistent across drugs.

In two head-to-head trials, pegylated interferon alfa-2a was associated with greater risk of serious adverse events (RR, 2.1; 95% CI, 1.0 to 4.5; I^2^=0%), withdrawals due to adverse events (RR, 7.6; 95% CI, 1.1 to 52; I^2^=38%), and any adverse event (RR, 1.7; 95% CI, 1.5 to 2.0; I^2^=55%) than lamivudine. There were no differences between entecavir and lamivudine (3 trials) or between tenofovir and adefovir (2 trials).

### Evidence

#### Antiviral Therapy Versus Placebo or No Treatment

Twenty-two trials of antiviral treatment for hepatitis B virus infection reported serious adverse events, withdrawals due to adverse events, or any adverse events during active treatment periods (Table 8 and Appendix B5).40-42,44-52,54-62,76 Data were available for adefovir (3 trials),40-42 interferon alfa-2b (8 trials),44-51 lamivudine (9 trials),52,54-60,76 telbivudine (1 trial),62 and tenofovir (1 trial).61 Sample sizes ranged from 35 to 651 patients, and active treatment periods (time on antiviral therapy) ranged from 1 month to 2.7 years. The proportion of patients with cirrhosis at baseline ranged from 5 to 44 percent in the 13 trials that reported this information.40,44-48,50,51,54,55,57,58,76 The trials that did not report cirrhosis information excluded patients with decompensated liver disease.41,42,49,52,56,59-62 One of the lamivudine trials52 and two of the interferon alfa-2b trials44,45 were rated poor quality, two trials were rated good quality,49,61 and the remainder fair quality (Appendix B6).40-42,46-48,50,51,54-60,62,76 Eight trials were conducted in the United States, Europe, Australia, or New Zealand;41,45-47,49,55,58,61 11 were conducted in regions with high HBV prevalence;44,48,50-52,54,56,57,59,60,62 and 3 were conducted in both countries with low and countries with high HBV prevalence.40,42,76

Table 8 Harms of Antiviral Therapy Versus Placebo or No Treatment

Author, Year | Duration, Followup | Time Period for Harms Data | Number, Country | Cirrhosis | Serious Adverse Events Treatment Vs. Control/No Treatment | Withdrawal Due to Adverse Events Treatment Vs. Control/No Treatment | Any Adverse Events Treatment Vs. Control/No Treatment | Quality | Notes
Adefovir Vs. Placebo
Hadziyannis 2003^40^ | 11 months + 1 month followup | Both | n=185 Canada, Greece, Israel, France, Italy, Australia, Taiwan, Singapore | 11% cirrhosis | 3% (4/123) vs. 7% (4/61); RR, 0.5 (95% CI, 0.1 to 1.9) | 0% (0/123) vs. 0% (0/61); RR, 0.5 (95% CI, 0.0 to 25) | 76% (94/123) vs. 74% (45/61); RR, 1.0 (95% CI, 0.9 to 1.2) | Fair | Any adverse event refers to those reported by at least 5% of patients
Jonas, 2008^41^ | 11 months | Time on treatment | n=83 United States and Europe | % cirrhosis NR^*^ | NR separately for relevant age group | 1.7% (1/56) vs. 0% (0/27); RR, 1.5 (95% CI, 0.1 to 35) | NR separately for relevant age group | Fair
Marcellin, 2003^42^ | 11 months + 1 month followup | Both | n=515 North America, Europe, Australia, and Southeast Asia | % cirrhosis NR^*^ | 10% (33/344) vs. 8% (13/167); RR, 1.2 (95% CI, 0.7 to 2.3) | 2.3% (8/344) vs. <1% (1/167); RR, 3.9 (95% CI, 0.5 to 31) | NR | Fair | N values calculated; combined treatment arms
Interferon Alfa-2b Vs. No Treatment
Bayraktar, 1993^44^ | 6 months | Time on treatment | n=35 Turkey | 29% cirrhosis | NR | 0% (0/25)^**^ | NR | Poor | Results reported for treated group only
Hadziyannis, 1990^45^ | 1 year + 1 year followup | Unclear | n=50 Greece | 44% cirrhosis | 0% (0/25)^**^ | NR | NR | Poor | Results reported for treated group only
Lampertico, 1997^46^ | 2 years + 1 year followup | Time on treatment | n=42 Italy | 17% cirrhosis | NR | 24% (5/21) vs. 0% (0/21); RR, 11 (95% CI, 0.65 to 187) | NR | Fair
Muller, 1990^47^ | 4 months + 6 months followup | Time on treatment | n=58 Germany | 5% cirrhosis | NR | 3.7% (1/27)^**^ | NR | Fair | Results reported for treated group only
Perez, 1990^48^ | 6 months (2nd phase) + 6 months followup | Time on treatment | n=35 Argentina | 14% cirrhosis | NR | 6% (1/18) vs. 0% (0/17); RR, 2.7 (95% CI, 0.1 to 62) | NR | Fair
Perrillo, 1990^49^ | 4 months + 6 months followup | Time on treatment | n=169 United States | % cirrhosis NR^*^ | NR | 3% (4/126) vs 0% (0/43); RR, 3.12 (95% CI, 0.17 to 57) | NR | Good
Sarin, 1996^50^ | 4 months + 1 year followup | Unclear | n=41 India | 44% cirrhosis | 0% (0/20)^**^ | NR | NR | Fair | Results reported for treated group only
Waked, 1990^51^ | 4 months + 1 year followup | Time on treatment | n=40 Egypt | 40% cirrhosis | 0% (0/20)^**^ | 0% (0/20)^**^ | NR | Fair | Results reported for treated group only; serious adverse effects inferred
Lamivudine Vs. Placebo
Ali, 2003^52^ | 6 months + 1 year followup | Unclear | n=74 Iraq | % cirrhosis NR^*^ | NR | 9.4% (3/32) vs. 0% (0/30); RR, 6.6 (95% CI, 0.4 to 122) | NR | Poor
Chan, 2007^54^ | 2 years + 6 months followup | Unclear | n=139 China | 27% cirrhosis | 15% (13/89) vs. 13% (6/47); RR, 1.1 (95% CI, 0.5 to 2.8) | NR | NR | Fair
Dienstag, 1999^55^ | 1 year + 4 months followup | Unclear | n=143 United States | 10% cirrhosis | 0% (0/66) vs 0% (0/71); RR, 1.1 (95% CI, 0.0 to 53) | NR | NR | Fair | Results inferred
Lai, 1997^56^ | 1 month + 1 month followup | Unclear | n=42 Hong Kong | % cirrhosis NR^*^ | 0% (0/36) vs. 0% (0/6); RR, 0.2 (95% CI, 0.0 to 8.8) | NR | NR | Fair | Combined treatment arms
Lai, 1998^57^ | 1 year | Time on treatment | n=358 Hong Kong, Taiwan, Singapore | 5% cirrhosis | 1.8% (5/285) vs. 0% (0/73);RR, 2.9 (95% CI, 0.2 to 51) | NR | 78.6% (224/285) vs. 77% (56/73);RR, 1.0 (95% CI, 0.9 to 1.2) | Fair | Combined treatment arms
Liaw, 2004^76^ | 2.7 years median + ≤1 year followup | Time on treatment | n=651 Several countries in Asia, Australia, New Zealand | 33% cirrhosis | 12% (54/436) vs. 18% (38/215); RR, 0.7 (95% CI, 0.5 to 1.0) | NR | 77% (335/436) vs. 83% (178/215); RR, 0.9 (95% CI, 0.9 to 1.0) | Fair | Any adverse event refers to those that occurred in greater than 10% of patients
Tassopoulo,1999^58^ | 6 months | Time on treatment | n=125 Greece | 15% cirrhosis | 5% (3/60) vs. 6% (4/65); RR, 0.8 (95% CI, 0.2 to 3.5) | 2% (1/60) vs. 0% (0/65); RR, 3.2 (95% CI, 0.1 to 78) | 47% (28/60) vs. 62% (40/65); RR, 0.8 (95% CI, 0.5 to 1.1) | Fair
Yalcin, 2004^59^ | 3 months + 1 year followup | Unclear | n=46 Turkey | % cirrhosis NR^*^ | 0% (0/13) vs. 0% (0/33); RR, 2.4 (95% CI, 0.1 to 116) | NR | NR | Fair
Yao, 1999^60^ See also: Yao, 2000^78^; Yao, 2009^79^ | 3 months + 9 months followup | Time on treatment | n=429 China | % cirrhosis NR^*^ | 0% (0/322) vs. 0% (0/107); RR, 0.3 (95% CI, 0.0 to 17) | 0% (0/322) vs. 0% (0/107); RR, 0.3 (95% CI, 0.0 to 17) | 43% (138/322) vs. 42% (45/107); RR, 1.0 (95% CI, 0.8 to 1.3) | Fair
Tenofovir Vs. Placebo
Murray, 2012^61^ | 1.4 years | Time on treatment | n=106 North America and Europe | % cirrhosis NR^*^ | 12% (6/52) vs 22% (12/54); RR, 0.5 (95% CI, 0.2 to 1.3) | NR | 85% (44/52) vs 89% (48/54); RR, 0.95 (95% CI, 0.8 to 1.1) | Good

* Decompensated liver disease as exclusion criterion.

** Excluded from meta-analyses.

Abbreviations: NR = not reported; RR = relative risk.

Serious adverse events. There were no statistically significant differences between antiviral therapy and placebo in risk of serious adverse effects (12 trials; RR, 0.8; 95% CI, 0.6 to 1.1; I^2^=0%)40,42,54-62,76 (Figure 12). Rates of serious adverse events on antiviral therapy ranged from 0 to 15 percent in the trials. When analyses were stratified by individual drug, results were consistent for lamivudine (8 trials; RR, 0.8; 95% CI, 0.6 to 1.1; I^2^=0%)54-60,76 and adefovir (2 trials; RR, 1.0; 95% CI, 0.4 to 2.1; I^2^=31%).40,42 Results were also consistent for telbivudine (RR, 1.1; 95% CI, 0.9 to 1.3)62 and tenofovir (RR, 0.5; 95% CI, 0.2 to 1.3)61 but were based on only one trial each.

Figure 12 Serious Adverse Events, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

Four lamivudine studies54-56,59 did not clearly report whether harms data were collected while patients were on antiviral therapy or included harms that occurred after discontinuing antiviral therapy. Excluding these trials did not affect the results for lamivudine (4 trials; RR, 0.7; 95% CI, 0.5 to 1.0; I^2^=0%) or the overall estimate (8 trials; RR, 8; 95% CI, 0.6 to 1.03; I^2^=0%). There were no poor-quality trials.

Three trials45,50,51 reported no serious adverse events in patients randomized to interferon alfa-2b but did not report data for patients who did not receive treatment.

Withdrawals due to adverse events. Antiviral therapy was associated with more withdrawals due to adverse effects than placebo (9 trials; RR, 4.0; 95% CI, 1.4 to 11; I^2^=0%)40-42,46,48,49,52,58,60 (Figure 13). Rates of withdrawal due to adverse events on antiviral therapy ranged from 0 to 24 percent in the trials, with only one event reported in patients on placebo or no treatment. Results were consistent for lamivudine (3 trials; RR, 4.8; 95% CI, 0.6 to 41; I^2^=0%),52,58,60 adefovir (3 trials; RR, 2.9; 95% CI, 0.5 to 16; I^2^=0%),40-42 and interferon alfa-2b (3 trials; RR, 4.8; 95% CI, 0.9 to 26; I^2^=0%),46,48,49 although estimates for individual drugs were imprecise and did not reach statistical significance.

Figure 13 Withdrawals Due to Adverse Events, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

Removing one poor-quality trial52 had no effect on the estimate (RR, 3.7; 95% CI, 1.2 to 11; I^2^=0%). Three trials reported rates of withdrawal due to adverse events of 0 to 3.7 percent on interferon alfa-2b but were excluded from the analysis because they did not report this outcome with placebo or no treatment.44,47,51

Any adverse events. There was no statistically significant difference between antiviral therapy and placebo in risk for experiencing any adverse event (7 trials; RR, 0.96; 95% CI, 0.9 to 1.0; I^2^=0%)40,57,58,60-62,76 (Figure 14). Rates of experiencing any adverse event on antiviral therapy ranged from 36 to 85 percent in the trials. Results were consistent for lamivudine (4 trials; RR, 0.95; 95% CI, 0.9 to 1.0; I^2^=14%),57,58,60,76 adefovir (1 trial; RR, 1.0; 95% CI, 0.9 to 1.2),40 and tenofovir (1 trial; RR, 0.95; 95% CI, 0.8 to 1.1),61 although the latter two drugs were evaluated in only one trial each. The estimate for telbivudine favored placebo but was imprecise, did not reach statistical significance, and was based on a single trial (RR, 2.5; 95% CI, 0.4 to 16).62 There were no poor-quality trials or trials that did not clearly report whether harms data were restricted to events that occurred while on antiviral therapy.

Figure 14 Any Adverse Events, Antiviral Therapy Versus Placebo or No Treatment

Abbreviations: df = degree of freedom; M-H = Mantel-Haenszel.

#### Entecavir, Pegylated Interferon Alfa-2a, or Tenofovir Versus Adefovir, Interferon Alfa-2b, Lamivudine, or Telbivudine

There were no differences between entecavir and lamivudine (3 trials)64,67,68 or between tenofovir and adefovir (2 trials)72 in risk of serious adverse events, withdrawal due to adverse events, or overall adverse events (Table 9). In two trials, pegylated interferon alfa-2a was associated with greater risk of serious adverse events (RR, 2.1; 95% CI, 1.0 to 4.5; I^2^=0%), withdrawals due to adverse events (RR, 7.6; 95% CI, 1.1 to 52; I^2^=38%), and any adverse event (RR, 1.7; 95% CI, 1.5 to 2.0; I^2^=55%) than lamivudine.70,71

Table 9 Head-to-Head Studies of Antiviral Therapy Reporting Harms of Treatment

Outcomes | Entecavir Vs. Lamivudine | Pegylated Interferon Alfa-2a Vs. Lamivudine | Tenofovir Vs. Adefovir
Serious adverse events | RR, 0.9 (95% CI, 0.6 to 1.3, I^2^=0%); 2 trials64,67 | RR, 2.1 (95% CI, 1.0 to 4.5, I^2^=0%); 2 trials70,71 | RR, 1.0 (95% CI, 0.5 to 1.8); 2 trials (1 publication, results pooled)72
Withdrawals due to adverse events | RR, 0.5 (95% CI, 0.1 to 1.9, I^2^=43%);3 trials64,67,68 | RR, 7.6 (95% CI, 1.1 to 52, I^2^=38%); 2 trials70,71 | Not reported
Any adverse event | RR, 1.0 (95% CI, 0.9 to 1.1, I^2^=34%); 3 trials64,67,68 | RR, 1.7 (95% CI, 1.5 to 2.0, I^2^=55%); 2 trials70,71 | RR, 1.0 (95% CI, 0.9 to 1.1); 2 trials (1 publication, results pooled)72

Note: Statistically significant results appear in bold type

Abbreviations: RR = relative risk.

## Key Question 9 Do Improvements in Intermediate Outcomes Improve Final Health Outcomes?

### Summary

Ten observational studies (n=22 to 818 and duration of followup from 4 to 9.9 years) found an association between various intermediate outcomes (virological remission, biochemical remission, histological improvement, HBeAg loss, or a composite intermediate outcome) and clinical outcomes (death, hepatocellular carcinoma, or a composite clinical outcome), but variability in patient populations (e.g., HBeAg status and prevalence of cirrhosis at baseline), intermediate and clinical outcomes evaluated, and methodological limitations make it difficult to draw strong conclusions. In some studies, results were not statistically significant. Three of the studies failed to address five key potential confounders (age, sex, fibrosis stages, HBV DNA level, and HBeAg status) through adjustment or restriction.

### Evidence

We identified 10 studies on the association between improvement in intermediate outcomes following antiviral therapy for chronic HBV infection and clinical outcomes (Tables 10 and 11 and Appendix B7).80-89 The studies varied in the intermediate outcomes that were evaluated. Four studies evaluated virological response (loss of HBV DNA and sustainability of HBV DNA loss),80-82,88 two studies evaluated biochemical remission (normalization of serum transaminase levels),83,87 one study evaluated HBeAg clearance,86 one study evaluated histological response (improvement in biopsy findings),84 and two studies evaluated composite intermediate outcomes (virological response plus HBeAg clearance89 or virological plus biochemical response85). The clinical outcomes also varied. Three studies evaluated death,82,83,89 two studies hepatocellular carcinoma,80,88 and the remainder various composite clinical outcomes (2 or more of the following: death, liver transplantation, cirrhosis, or complications of cirrhosis). Four studies focused on HBeAg-positive patients83,84,86,89 and the remainder on HBeAg-negative patients.80-82,85,87,88 Sample sizes ranged from 22 to 818 patients, and duration of followup from 4 to 9.9 years. In three studies, the antiviral treatment was lamivudine;80,82,88 in the remainder, patients received interferon. Two studies included only patients with cirrhosis,80,83 one study excluded patients with cirrhosis,81 and in the other studies, the proportion of patients with cirrhosis ranged from 12 to 60 percent. Seven studies were rated fair quality80-82,85,86,88,89 and three studies poor quality (Appendix B8).83,84,87 Important methodological shortcomings included unclear blinding status of outcome assessors and failure to report loss to followup. In addition, the poor-quality studies did not address at least four of five key confounders (age, sex, fibrosis stage, HBV viral load, HBeAg status) through adjustment or restriction (e.g., enrolling only HBeAg-negative or HBeAg-positive patients).

Table 10 Studies of Association Between Intermediate and Final Health Outcomes

Author, Year Country | Study Design | Intermediate Outcome Evaluated: Proportion of Patients With Intermediate Outcome | Treatment Duration of Followup | Characteristics of HBV Infection | Age, Sex, Race | Number Receiving Antiviral Treatment Lost to Followup | Quality
Andreone, 2004^80^ Italy | Cohort (unclear if prospective or retrospective) | No virological breakthrough (HBV DNA became undetectable on treatment and remained undetectable): 41% | Lamivudine Median 42 months | HBeAg positive: None ALT (mean): 192 Serum HBV DNA (mean, pg/ml): 16 Cirrhosis: 100% | Mean age: 53 years Male: 82% Race: NR | n=22 Lost to followup: Unclear | Fair
Baltayiannis, 2006^81^ Greece | Cohort (unclear if prospective or retrospective) | Virological response (HBV DNA <10,000 copies/ml at 6 months of treatment): 35% | Interferon alfa 6 years | HBeAg positive: None ALT (median): 177 Serum HBV DNA (median, copies/mL): 1.2 × 10^6^ Cirrhosis: Excluded | Mean age: 51 years Male: 63% Race: NR | n=63 Lost to followup: 1 (1.6%) | Fair
Di Marco, 2004^82^ Italy | Retrospective cohort | No virological breakthrough (HBV DNA <10^5^ copies/ml throughout followup after achieving undetectability): 39% | Lamivudine 4 years | HBeAg positive: Excluded ALT >2 times ULN: 65% Serum HBV DNA: NR Cirrhosis on histology: 25% | Mean age: 49 years Male: 83% Race: NR | n=656 Lost to followup: NR; 40 patients had no virological response and were excluded from analysis | Fair
Fattovich, 1997^83^ Italy | Cohort (unclear if prospective or retrospective) | Biochemical remission (normalization of ALT levels): 28% | Interferon alfa Mean 7 years | HBeAg positive: All ALT (mean): 5.3 times upper limit of normal Serum HBV DNA: NR Cirrhosis: 100% | Mean age: 47 years Male: 85% Race: 100% white | n=40 Lost to followup: NR for treated subgroup | Poor
Hui, 2008^84^ China (Hong Kong) | Cohort (unclear if prospective or retrospective) | Histological response (improvement of 2 points or more on HAI score after end of treatment): 40% | Interferon alfa-2a or -2b Median 9.9 years | HBeAg positive: All ALT (mean): 113 Serum HBV DNA >10^5^ copies/ml: 100% Cirrhosis: 12% | Mean age: 30 years Male: 78% Race: NR | n=89 Lost to followup: NR | Poor
Lampertico, 2003^85^ Italy | Cohort (unclear if prospective or retrospective) | Sustained virological and biochemical response (normalization of serum ALT and clearance of HBV DNA): 30% | Interferon alfa-2b 68 months | HBeAg positive: None ALT (mean): 204 HBV DNA detectable: 61% Ishak F4-F6 fibrosis: 60% | Men age: 46 years Female: 13% Race: NR | n=101 Lost to followup: 4 (4.0%) | Fair
Lau, 1997^63^ United States | Cohort (originally enrolled in RCTs) | Response (sustained loss of HBV DNA and clearance of HBeAg within 1 year of starting treatment): 30% | Interferon alfa Mean 6.2 years | HBeAg positive: All ALT (median): 154 Serum HBV DNA (mq/mL): 4,843 Cirrhosis: 17% | Mean age: 41 years Male: 83% Race: 94% white, 6% black | n=103 Lost to followup: 8 (7.8%); assumed to be alive and without liver-related complications | Fair
Niederau, 1996^86^ Europe | Prospective cohort | Loss of HBeAg after therapy: 51% | Interferon alfa-2b Mean 50 months | HBeAg positive: All HBsAg clearance: 9.7% ALT: NR AST: NR HBV DNA: NR Fibrosis stage: NR Cirrhosis: NR (Child-Pugh class B or C excluded) | Mean age: NR Female: NR Race: NR | n=103 Lost to followup: None | Fair
Papatheodoridis, 2001^87^ Greece | Cohort (unclear if prospective or retrospective) | Sustained biochemical response (normalization of ALT at the end of interferon therapy and persistently normal ALT levels throughout the post-treatment followup period): 27% | Interferon alfa Mean 6.0 years | HBeAg positive: Excluded ALT (median): 112 Serum HBV DNA (median, pg/ml): 4.4 Cirrhosis: 27% | Mean age: 47 years Male: 83% Race: NR | n=209 Lost to followup: 9 (4.3%) | Poor
Papatheodoridis, 2011^88^ Greece | Retrospective cohort | Virological remission (HBV DNA <200 IU/ml throughout therapy): 28% | Lamivudine Median 4.7 years | HBeAg positive: Excluded ALT (median): 98 Serum HBV DNA (median, ×10^3^ IU/ml): 400 Cirrhosis: 26% | Mean age: 54 years Male: 72% Race: NR | n=818 Lost to followup: 180 (22%) | Fair

Abbreviations: ALT = alanine aminotransferase; AST = aspartate aminotransferase; HAI = histology activity index; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; NR = not reported; RCT = randomized, controlled trial; ULN = upper limit of normal.

Table 11 Hazard Ratios for Associations Between Intermediate and Final Health Outcomes

HBeAg Status Author, Year Country | Confounders Adjusted for in Analysis | Death | Hepatocellular Carcinoma | Composite Outcomes | Quality
HBeAg-Positive Patients
Fattovich, 1997^83^ Italy | Age Sex Symptoms Hepatic stigmata Splenomegaly AST ALT AST/ALT ratio Bilirubin Albumin Gamma-globulins Platelets HBeAg clearance ALT normalization All patients HBeAg positive | Biochemical remission vs. no remission: adjusted HR, 0.09 (95% CI, 0.01 to 0.71) | NR | NR | Poor
Hui, 2008^84^ China (Hong Kong) | Fibrosis HBV DNA level All patients HBeAg positive | NR | NR | Histological response on HAI score vs. no response: adjusted HR, 0.62 (95% CI, 0.06 to 6.9) | Poor
Lau, 1997^89^ United States | Cirrhosis Age Sex ALT AST All patients HBeAg positive | Responder (virological response and HBeAg clearance) vs. nonresponder: adjusted HR, 0.59 (95% CI, 0.20 to 1.67)^a^ | NR | Responder vs. nonresponder: adjusted HR, 0.07 (95% CI, 0.02 to 0.33)^b^ | Fair
Niederau, 1996^86^ Europe | Age Sex Baseline HBV DNA Duration of hepatitis Preexisting cirrhosis All patients HBeAg positive | NR | NR | HBeAg loss vs. no loss: adjusted HR, 0.06 (95% CI, 0.01 to 0.61)^c^ | Fair
HBeAg-Negative Patients
Andreone, 2004^80^ Italy | Age Sex Child-Pugh class ALT HBV viral load Albumin Bilirubin Prothrombin activity Alpha-fetoprotein Previous interferon therapy Smoking status Months of treatment All patients HBeAg negative | NR | No virological breakthrough vs. breakthrough: adjusted HR, 0.10 (95% CI, 0.01 to 0.77) | NR | Fair
Baltayiannis, 2006^81^ Greece | Age Sex Alcohol use ALT >200 IU/L at baseline HBV DNA >10,000 copies/ml at baseline Histologic grade >9 Histologic stage >2 All patients HBeAg negative | NR | NR | Virological response at 6 months vs. no virological response: adjusted HR, 0.24 (95% CI, 0.06 to 0.96)^d^ | Fair
Di Marco, 2004^82^ Italy | Age Sex HBV DNA level ALT Hepatic flare after virological breakthrough Previous interferon therapy Cirrhosis All patients HBeAg negative | No virological breakthrough vs. breakthrough: adjusted HR, 0.34 (95% CI, 0.15 to 0.80) | NR | NR | Fair
Lampertico, 2003^85^ Italy | Age Sex ALT HBV viral load IgM anti-HBc level Necroinflammatory grade Fibrosis stage All patients HBeAg negative | NR | NR | Sustained virological and biochemical response vs. no sustained response: adjusted HR, 0.13 (95% CI, 0.03 to 0.55)^e^ | Fair
Papatheodoridis, 2001^87^ Greece | Cirrhosis Age All patients HBeAg negative | NR | NR | Death or liver transplantation Sustained biochemical response vs. no sustained biochemical response: adjusted HR, 0.48 (95% CI, 0.23 to 1.0) Severe clinical complications^f^ Sustained biochemical response vs. no sustained biochemical response: adjusted HR, 0.53 (95% CI, 0.29 to 0.91) | Poor
Papatheodoridis, 2011^88^ Greece | Age Sex Liver disease severity ALT AST Bilirubin Albumin Hemoglobin Platelet count HBV DNA Interferon alfa in the past All patients HBeAg negative | NR | Virological remission under therapy vs. no virological remission: adjusted HR, 0.77 (95% CI, 0.35 to 1.69)^g^ | NR | Fair

a Only adjusted for age and sex.

b Outcome was death, variceal hemorrhage, ascites, or encephalopathy.

c Outcome was death; need for liver transplantation; development of ascites, jaundice, or hepatic encephalopathy; or occurrence of, or bleeding from, esophageal varices.

d Outcome was death or liver complications (not defined).

e Outcome was cirrhosis, ascites, jaundice, hepatic encephalopathy, gastroesophageal bleeding due to portal hypertension, or hepatocellular carcinoma.

f Outcome was death, liver transplantation, liver decompensation (ascites, variceal bleeding, hepatic encephalopathy), and hepatocellular carcinoma.

g Outcome was HBV-related decompensated liver cirrhosis or hepatocellular carcinoma.

Abbreviations: ALT = alanine aminotransferase; anti-HBc = antibody to hepatitis B core antigen; AST = aspartate aminotransferase; HAI = histology activity index; HBeAg = hepatitis B e antigen; HBV = hepatitis B virus; HR = hazard ratio; IgM = immunoglobulin M; NR = not reported.

The variability in patient populations (e.g., HBeAg status and prevalence of cirrhosis at baseline), intermediate and clinical outcomes evaluated, and study quality makes it difficult to draw strong conclusions regarding the association between achieving intermediate outcomes after antiviral treatment and improvement in clinical outcomes (Table 12). In all studies of both HBeAg-positive and HBeAg-negative patients, estimates of risk favored achieving the intermediate outcomes, although results were not always statistically significant. For death, one study evaluated biochemical remission versus no biochemical remission (adjusted HR, 0.09; 95% CI, 0.01 to 0.71),83 one study evaluated a composite intermediate outcome (virological response plus HBeAg clearance: adjusted HR, 0.59; 95% CI, 0.20 to 1.67)89 in HBeAg-positive patients, and one study evaluated virological breakthrough in HBeAg-negative patients (adjusted HR, 0.34; 95% CI, 0.15 to 0.80).82 For hepatocellular carcinoma, one study evaluated maintenance of virological remission (no virological breakthrough: adjusted HR, 0.10; 95% CI, 0.01 to 0.77)80 and one study evaluated achieving virological remission during therapy (adjusted HR, 0.77; 95% CI, 0.35 to 1.69)88 in HBeAg-negative patients. For composite clinical outcomes, one study evaluated HBeAg loss (adjusted HR, 0.06; 95% CI, 0.01 to 0.61)86 and one study evaluated a 2-point improvement on the HAI score (adjusted HR, 0.62; 95% CI, 0.06 to 6.9)84 in HBeAg-positive patients. One other study evaluated a composite intermediate outcome (virological clearance plus HBeAg loss) in HBeAg-positive patients (adjusted HR, 0.07; 95% CI, 0.02 to 3.3),89 and three studies evaluated virological response (adjusted HR, 0.24; 95% CI, 0.06 to 0.96),81 biochemical response (adjusted 0.48; 95% CI, 0.23 to 1.0),88 or a composite intermediate outcome (virological plus biochemical response: adjusted HR, 0.53; 95% CI, 0.29 to 0.91)85 in HBeAg-negative patients. Evidence was too limited and heterogeneous to draw strong conclusions regarding the effects on conclusions of methodological limitations, differences in intermediate or clinical outcomes evaluated, or variability in baseline cirrhosis.

Table 12 Associations Between Intermediate Outcomes and Final Health Outcomes

Intermediate Outcome | Death | Hepatocellular Carcinoma | Composite Outcome
ALT normalization | 1 study;83 HR, 0.09 (95% CI, 0.01 to 0.71) | No studies | 1 study;87 HR, 0.48 (95% CI, 0.23 to 1.0)^*^
Composite intermediate outcome | 1 study;89 HR, 0.59 (95% CI, 0.20 to 1.67) | No studies | 2 studies;85,89 HR, 0.07 (95% CI, 0.02 to 0.33); HR, 0.13 (95% CI, 0.03 to 0.55)^*^
HBeAg loss | No studies | No studies | 1 study;86 HR, 0.06 (95% CI, 0.01 to 0.61)
Histological response | No studies | No studies | 1 study;84 HR, 0.62 (95% CI, 0.06 to 6.9)
Virological response | 1 study;82 HR, 0.34 (95% CI, 0.15 to 0.80)^*^ | 2 studies;80,88 HR, 0.10 (95% CI, 0.01 to 0.77);^*^ HR, 0.77 (95% CI, 0.35 to 1.69)^*^ | 1 study;81 HR, 0.24 (95% CI, 0.06 to 0.96)^*^

* Study performed in HBeAg-negative patients.

Abbreviations: ALT = alanine aminotransferase; HBeAg = hepatitis B e antigen; HR = hazard ratio.