# Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,32,33 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and Key Questions for this review. Evidence-based Practice Center (EPC) investigators created an analytic framework showing the Key Questions and the patient populations, interventions, and outcomes of the review (Figure 1).

Figure 1 Analytic Framework

Abbreviations: HBeAg = hepatitis B e antigen; HBV = hepatitis B virus; KQ = key question.

The Key Questions are—

Key Question 1. What are the benefits of screening for HBV versus no screening in asymptomatic, nonpregnant adolescents and adults on morbidity, mortality, and disease transmission?

Key Question 2. What are the harms of screening for HBV infection (e.g., labeling, anxiety, and harms of confirmatory tests, including biopsy)?

Key Question 3. How well do different screening strategies identify individuals with HBV infection (e.g., strategies that target persons from high-prevalence countries, men who have sex with men, injection drug users, immunization history, or other risk factors)?

Key Question 4. In nonpregnant adolescents and adults with no evidence of HBV immunity on screening, how effective is HBV vaccination for improving clinical outcomes?

Key Question 5. In nonpregnant adolescents and adults with chronic HBV infection, how effective is antiviral treatment at improving intermediate outcomes (virological or histological improvement or clearance of HBeAg)?

Key Question 6. In nonpregnant adolescents and adults with chronic HBV infection, how effective is antiviral treatment at improving health outcomes?

Key Question 7. In nonpregnant adolescents and adults with chronic HBV infection, how effective is education or behavior change counseling in reducing transmission and improving health outcomes?

Key Question 8. What are the harms associated with antiviral treatment for HBV infection?

Key Question 9. Do improvements in intermediate outcomes improve final health outcomes?

The overarching Key Questions (1 and 2) in the analytic framework focus on direct evidence on the effects of screening for HBV infection on health outcomes compared with not screening. When such direct evidence is sparse or unavailable, an indirect chain of evidence can be used to link screening with health outcomes, as shown in the rest of the analytic framework. Critical gaps in any of the links of the indirect chain of evidence can make it difficult or impossible to reliably estimate benefits and harms of screening. Links in the chain of indirect evidence include the performance of testing strategies for identifying individuals with HBV infection and the effectiveness of treatments in those with HBV infection, as well as any harms from the screening test and subsequent diagnostic tests and treatments. We did not re-review the diagnostic accuracy of HBV antibody testing and followup testing for viremia, which is considered accurate for diagnosing chronic infection.3

This review differs from the prior brief USPSTF evidence update2 in that it included Key Questions on the benefits and harms of antiviral treatment, benefits of education or behavior change counseling, and the association between improvements in intermediate and clinical outcomes and excluded Key Questions related to prenatal screening and immunization of children.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials (through January 2014), the Cochrane Database of Systematic Reviews (2005 through January 2014), Ovid MEDLINE^®^ (1946 through January 2014), and PsycINFO^®^ (1806 through January 2014) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). For Key Questions related to screening, we included randomized trials, cohort studies, case-control studies, and cross-sectional studies that compared different screening strategies in asymptomatic adults without known liver enzyme abnormalities and reported clinical outcomes (including harms) or the sensitivity and number needed to screen to identify one HBV-infected person (or the data to calculate these parameters). For Key Questions related to treatment, we included placebo-controlled trials of vaccination in adults without known immunity to HBV infection and trials of counseling in HBV-infected people regarding high-risk behaviors. For antiviral therapy, we included trials of patients that compared monotherapy with an FDA-approved medication versus placebo or no treatment and reported clinical outcomes (mortality, cirrhosis, hepatic decompensation, hepatocellular carcinoma, need for transplantation, quality of life, or disease transmission) or intermediate outcomes (normalization of aminotransferase levels, decrease in HBV DNA level, improvement in liver histology, HBeAg clearance or development of anti-HBe in HBeAg-positive patients). We also included randomized trials of currently recommended first-line antiviral therapies (pegylated interferon, entecavir, and tenofovir)27 versus older antiviral therapies (adefovir, nonpegylated interferon, lamivudine, or telbivudine).

Studies of treatment were excluded if they evaluated non–FDA-approved or discontinued drugs, with the exception of placebo-controlled trials of interferon alfa-2a. Although interferon alfa-2a has been supplanted by pegylated interferon and is no longer available in the United States, we included trials of interferon alfa-2a that reported clinical outcomes because evidence from placebo-controlled trials of nonpegylated interferon alfa-2b and pegylated interferon alfa-2a on clinical outcomes was sparse. For harms, we included randomized trials and controlled observational studies that reported withdrawals due to adverse events, serious adverse events, or overall adverse events. For harms, we also included head-to-head trials for currently recommended first-line antiviral therapies. For Key Question 9, we included cohort studies that reported adjusted risk estimates for the association between clinical outcomes and either achieving or not achieving an intermediate outcome after antiviral treatment (e.g., clearance of HBeAg or HBV DNA from serum, normalization of serum transaminases, or histological improvement).

We excluded trials of antiviral therapy that focused on primary nonresponders to prior antiviral therapy or patients with virological relapse, and we did not evaluate development of drug resistance as an outcome. We excluded studies of patients with HIV or HCV coinfection, patients on hemodialysis, and transplant patients. We excluded systematic reviews of antiviral therapies unless we were unable to abstract the primary studies because they were in a foreign language. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. Two investigators independently applied criteria developed by the USPSTF32,33 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, poor) using methods developed by the USPSTF, based on the number, quality, and size of studies; consistency of results between studies; and directness of evidence.32,33

We conducted meta-analyses to calculate relative risks for clinical outcomes (death, hepatocellular carcinoma, and incident cirrhosis), intermediate outcomes (HBeAg loss, HBV viral clearance, normalization of AST levels, and histological improvements), and harms (serious adverse events, withdrawals due to adverse events, and any adverse events) with antiviral drugs versus placebo/no treatment and for first-line antivirals versus other antivirals. We used the Mantel-Haenszel random-effects model with RevMan software (Review Manager Version 5.2, Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration, 2012). Primary analyses for intermediate and clinical outcomes were based on total followup (including time following discontinuation of antiviral therapy), although we conducted sensitivity analysis restricted to events that occurred while patients were receiving antiviral therapy. For all analyses, we stratified results by antiviral drug. Statistical heterogeneity was assessed using the I^2^ statistic.34 We performed additional analyses in which trials were stratified by study quality, duration of followup (shorter or longer than 1 year), HBeAg status, and inclusion of patients with cirrhosis.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix A6) and was posted for public comment. In response to public comments, we made minor revisions in the Introduction to more accurately describe the definition and natural history of chronic HBV infection.