# Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This report was commissioned by the U.S. Preventive Services Task Force (USPSTF) in order to update its 2004 recommendation on screening for hepatitis B virus (HBV) infection in nonpregnant adolescents and adults.1 The 2004 USPSTF recommendation was based on an evidence review with literature searches conducted through 2001.^2^

In 2004, the USPSTF recommended against screening asymptomatic persons in the general population for chronic HBV infection (D recommendation), based on a lack of evidence showing that screening improves morbidity or mortality associated with HBV infection; that the prevalence of HBV infection is low in the general population; and that the majority of infected individuals do not develop chronic infection, cirrhosis, or other HBV-related liver disease.1 The USPSTF noted the poor predictive value of screening strategies for identifying persons at high risk for infection and limited evidence on the effectiveness of treatment interventions.1 The USPSTF also pointed out that routine vaccination has reduced the number of new HBV infections, particularly for children and adolescents, decreasing the burden of chronic HBV infection.

In 2009, the USPSTF separately addressed prenatal screening for HBV infection, reaffirming its 2004 recommendation for screening at the first prenatal visit (A recommendation).3,4 The current review focuses on screening nonpregnant persons; the USPSTF is not updating its recommendation on prenatal screening at this time.

## Condition Definition

HBV is a double-stranded DNA virus enclosed in a nucleocapsid protein (core antigen) surrounded by an envelope protein (surface antigen, or sAg).5 Serologic markers are usually the initial tests used to determine HBV infection status (Table 1); subsequent tests in persons with markers indicating active infection are performed to determine the presence and level of circulating HBV DNA. Acute HBV infection (within 6 months after infection) is typically characterized by the initial appearance of HBV surface antigen (HBsAg) without other serologic markers, followed by the appearance of immunoglobin M (IgM) antibody to the HBV core antigen (anti-HBc).6,7 Chronic infection is characterized by the persistent presence of HBsAg for longer than 6 months; HBV DNA levels can fluctuate and are not a reliable marker of chronic infection.6,7 The presence of HBV e antigen (HBeAg) is usually associated with high levels of HBV DNA in serum and high infectivity.8,9 Resolution of HBV infection and immunity are typically characterized by disappearance of HBsAg and appearance of antibody to HBV surface antigen (anti-HBs) as well as anti-HBc. Although disappearance of HBeAg and appearance of antibody to HBeAg (anti-HBe) eventually occurs in most patients with chronic HBV infection, typically correlating with low levels of HBV DNA in serum and remission of liver disease, patients (primarily from southern Europe or Asia) who are HBeAg negative due to mutations that prevent HBeAg expression can have persistent active disease.

Table 1 Typical Interpretation of Serologic Test Results for Hepatitis B Infection

Serologic Marker | | | | Interpretation
HBsAg | Total Anti-HBc | IgM Anti-HBc | Anti-HBs | Interpretation
- | - | - | - | Never infected
+^*^ | - | - | - | Early acute infection; transient (up to 18 days) after vaccination
+ | + | + | - | Acute infection
- | + | + | + or - | Acute resolving infection
- | + | - | + | Recovered from past infection and immune
+ | + | - | - | Chronic infection
- | + | - | - | False-positive (i.e., susceptible), past infection, “low-level” chronic infection,^**^ or passive transfer of anti-HBc to infant born to HBsAg-positive mother
- | - | - | + | Immune if concentration is ≥10 mIU/mL after vaccine series completion; passive transfer after hepatitis B immune globulin administration

* To ensure that an HBsAg-positive test result is not a false-positive, samples with reactive HBsAg results should be tested with a licensed neutralizing confirmatory test if recommended in the manufacturer's package insert.

** Persons positive only for anti-HBc are unlikely to be infectious except under unusual circumstances in which they are the source of direct percutaneous exposure of susceptible recipients to large quantities of virus (e.g., blood transfusion or organ transplant).

Note: Reproduced with permission from Mast et al, 2006.^6^

Abbreviations: - = negative test result; + = positive test result; anti-HBc = antibody to hepatitis B core antigen; anti-HBs = antibody to HBsAg; HBsAg = hepatitis B surface antigen; IgM = immunoglobulin M; mIU/mL = milli-International Units per milliliter.

## Prevalence and Burden of Disease

The reported incidence of acute symptomatic HBV infections in the United States has fallen from over 20,000 cases annually in the mid-1980s to 2,890 cases in 2011.^10^ Due to underreporting, the actual number of cases is estimated to be 6.5 times higher than the number of reported cases.10 From 2000 to 2010, the incidence of acute HBV infection declined among all age groups.11 In 2010, the highest rate of new HBV infections was among persons age 30 to 39 years (2.33 cases/100,000 population), with males and black persons at highest risk.11

As of 2008, an estimated 704,000 people in the United States were chronically infected with HBV.12 In 2010, there were an estimated 0.5 deaths associated with HBV infection per 100,000 persons, with the highest death rates among persons age 55 to 64 years, persons of “non-white, non-black” race, and males.13

## Etiology and Natural History

HBV is spread through percutaneous or mucous membrane exposure to blood or blood-containing body fluids (serum, semen, or saliva).6,9,14 The liver is the primary site of viral replication. Infected individuals may be asymptomatic or present with symptoms of acute infection, such as nausea, anorexia, fatigue, low-grade fever, and abdominal pain.5 Jaundice may also be present, and elevated liver enzymes can be seen on standard assays.

If symptoms of acute disease occur, they can take from 6 weeks to 6 months to appear.15 Acute infection generally self-resolves in 2 to 4 months, although mortality in this phase is about 1 percent. The risk of progression from acute to chronic infection varies according to age. Risk of chronic infection is more than 90 percent in infants, 30 percent in children age 1 to 5 years, and less than 5 percent in those older than age 5 years.9,15 Chronic infection spontaneously resolves in 0.5 percent of individuals annually. Some chronically infected individuals are asymptomatic, although others experience a range of symptoms, including nonspecific symptoms of fatigue or other symptoms related to hepatitis, cirrhosis, or hepatocellular carcinoma.15 Patients can also transition between different phases of chronic HBV infection. The phases include the immune tolerant phase, characterized by the presence of HBeAg and high levels of HBV viremia but absence of liver disease; the immune active or chronic hepatitis phase, characterized by high levels of HBV viremia and active liver inflammation, with presence or absence of HBeAg or presence of anti-HBe; and the inactive phase, characterized by the presence of anti-HBe, normal liver aminotransferase levels, and low or undetectable levels of HBV viremia. Although the course of chronic HBV infection varies widely, potential long-term sequelae include cirrhosis, hepatic decompensation, and hepatocellular carcinoma.16 Death from cirrhosis or hepatocellular carcinoma is thought to occur in 15 to 25 percent of those chronically infected with HBV. Increased viral load is associated with greater risk of cirrhosis, hepatocellular carcinoma, and liver-related mortality.17,18 Chronically infected persons are a reservoir for person-to-person transmission of HBV infection.

## Risk Factors/Indicators

People born in countries with an HBV prevalence of ≥2 percent account for 47 to 95 percent of the chronically infected population in the United States, although marked decreases in prevalence have been seen among younger persons born in these countries due to universal immunization programs.19-21 Regions of the world with very high HBV prevalence (≥8%) include most of Asia, most of Africa, Australasia with the exception of Australia and New Zealand, and parts of South America.15 Persons at higher risk for acute HBV infection include men, black persons, and persons age 30 to 39 years.11 Risk factors for HBV infection include having household contacts or sex partners with HBV infection (prevalence of chronic infection, 3 to 20%), male sexual activity with other males (1.1 to 2.3%), injection drug use (2.7 to 11%), and HIV-positive status (6 to 15%).9,11,15,22,23 Settings with high proportions of persons at risk for HBV infection include sexually transmitted disease (STD) clinics, HIV testing and treatment centers, health care settings that target services toward injection drug users (IDUs) and men who have sex with men, correctional facilities, hemodialysis facilities, and institutions and nonresidential daycare centers for developmentally disabled persons.6

## Rationale for Screening and Screening Strategies

Identification of asymptomatic persons with chronic HBV infection through screening may identify those who would benefit from earlier evaluation and management of their disease. Data on the proportion of persons with chronic HBV infection in the United States who are not aware of their infection status are limited, although in studies of Asian-born persons living in the United States, the proportion is approximately one-third.15 Identification of asymptomatic chronic HBV infection could also lead to reductions in behaviors associated with more rapid progression of liver disease or interventions to decrease transmission of HBV and identify close contacts who might also benefit from testing.

## Interventions and Treatment

### Vaccination

Screening could identify persons without prior evidence of HBV exposure (anti-HBs and anti-HBc negative), who could benefit from vaccination to protect against future infection. In the United States, current policies are for universal vaccination of all infants at birth, catch-up vaccination of adolescents, and vaccination of high-risk groups, such as health care workers, IDUs, household contacts of patients with HBV infection, men who have sex with men, and persons with end-stage renal disease. HBV vaccines in the United States contain between 10 to 40 micrograms of HBsAg protein/mL for adolescents and adults, and generally involve at least three intramuscular doses administered at 0, 1, and 6 months.6,9 Vaccination results in ≥90 percent protective antibody response after the third dose in adults and >95 percent in adolescents, although protective anti-HBs titers may be attained in some persons after one or two doses.6, 9 As of 2011, universal vaccination of children has been implemented in over 190 countries, with 81 countries targeting newborns.24,25 The widespread implementation of universal vaccination strategies throughout the world has been credited with marked decreases in HBV incidence, particularly among younger persons.26

### Treatment

Currently seven antiviral drugs are approved by the U.S. Food and Drug Administration (FDA) for treatment of chronic HBV infection: interferon alfa-2b, pegylated interferon alfa-2a, lamivudine, adefovir, entecavir, telbivudine, and tenofovir. A number of combination therapies and drugs have also been evaluated but are not FDA approved and not recommended as first-line treatment due to unclear advantages over monotherapy in most patients, particularly in those at low risk for developing drug resistance.27,28 Drugs for HBV infection are broadly categorized as either interferons or nucleoside/nucleotide analogs.21,28-30 The interferons affect viral replication as well as immune modulation.8,27 Nucleoside/nucleotide analogues (lamivudine, adefovir, entecavir, and others) compete with binding sites on the HBV reverse transcriptase.

The choice of antiviral medication varies according to patient characteristics and disease activity. Factors that affect the decision to treat include the HBV DNA level, serum transaminase levels, and HBeAg status; sustained remission is rare in the absence of treatment in patients with HBeAg-negative HBV infection.27 Biopsy may be performed in some patients to establish the degree of liver inflammation and fibrosis.27,28 In many cases, pegylated interferon alfa-2a, entecavir, or tenofovir are suggested as first-line drugs due to their tolerability, efficacy, and lower rates of inducing resistance.27,28

The goal of treatment is to achieve sustained suppression of HBV replication and remission of liver disease in order to prevent cirrhosis, hepatic failure, and hepatocellular carcinoma.21,29 The recommended duration of treatment varies depending on the HBeAg status, presence of cirrhosis, time required to achieve HBV DNA suppression, and choice of medication.15,27,28 Interferon-based therapy is usually recommended for shorter duration of treatment than non–interferon-based therapy, in part due to limited tolerability and additional immunomodulatory effects of interferons.27,28

Other treatments in patients with chronic HBV infection could include counseling or education to reduce behaviors associated with accelerated progression of liver disease (such as alcohol use) or transmission, or surveillance with imaging tests to identify hepatocellular carcinoma.

## Current Clinical Practice

Screening for HBV infection is usually performed by testing for HBsAg, anti-HBs, and anti-HBc.27 The Centers for Disease Control and Prevention (CDC) recommends that FDA-approved tests be used to screen for HBsAg and a confirmatory test performed for initially reactive results.15 In persons with serologic findings suggesting chronic infection, followup includes testing for viremia.

Current U.S. screening practices for HBV and rates of HBV testing are largely unreported. As described below, some groups recommend that screening be targeted to higher risk groups, including persons born in high-prevalence countries.15,27

## Recommendations of Other Groups

The CDC15 and the American Association for the Study of Liver Diseases (AASLD)27 both recommend HBV screening for the following high-risk persons:

- All foreign-born persons from regions with HBsAg prevalence ≥2 percent, regardless of vaccination history
- U.S.-born persons not vaccinated as infants whose parents were born in regions with HBsAg ≥8 percent
- IDUs
- Men who have sex with men
- Immunosuppressed persons
- Persons with elevated alanine aminotransferase (ALT)/aspartate aminotransferase (AST) of unknown etiology
- Hemodialysis patients
- Household contacts and sex partners of HBsAg-positive persons
- Persons with HIV
- Pregnant women and infants born to HBV-infected mothers

In addition, the CDC recommends screening of blood, organ, or tissue donors; persons with occupational or other exposures to infectious blood or body fluids; and persons who received HBV vaccination as adolescents or adults who have high-risk behaviors.15 The AASLD recommends screening of persons with multiple sex partners or a history of STD, inmates of correctional facilities, and individuals with hepatitis C virus (HCV) infection.27 The Institute of Medicine endorses screening in high-risk groups.31