# Evidence and Quality Tables

Appendix B1 Screening Strategies Evidence Table

Appendix B2 Screening Strategies Quality Assessment

Appendix B3a Vaccination Studies Evidence Table, Randomized, Controlled Trials

Appendix B3b Vaccination Studies Evidence Table, Systematic Reviews

Appendix B4a Vaccination Studies Quality Assessment, Randomized, Controlled Trials

Appendix B4b Vaccination Studies Quality Assessment, Systematic Reviews

Appendix B5 Treatment Trials Evidence Table

Appendix B6 Treatment Trials Quality Assessment

Appendix B7 Studies of Association Between Intermediate and Final Health Outcomes Evidence Table

Appendix B8 Studies of Association Between Intermediate and Final Health Outcomes Quality Assessment