# Detailed Methods

## Appendix A1 Search Strategies

### Screening - Key Questions 1, 2

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. exp Hepatitis B/
2. exp Hepatitis B virus/
3. hepatitis b.mp.
4. hbv.mp.
5. or/1-4
6. Mass Screening/
7. 5 and 6
8. ((hepatitis b or hbv) adj1 screen$).mp.
9. 7 or 8
10. Pregnancy/
11. 9 not 10
12. limit 11 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
13. limit 12 to english language
14. limit 12 to abstracts
15. 13 or 14

EBM Reviews - Cochrane Central Register of Controlled Trials
1. Hepatitis B/
2. Hepatitis B virus/
3. hepatitis b.mp.
4. hbv.mp.
5. or/1-4
6. Mass Screening/
7. 5 and 6
8. ((hepatitis b or hbv) adj1 screen$).mp.
9. 7 or 8
10. Pregnancy/
11. 9 not 10

PsycINFO
1. hepatitis b.mp.
2. hbv.mp.
3. 1 or 2
4. exp Screening Tests/ or exp Screening/ or screen$.mp.
5. 3 and 4

### Effectiveness of Screening Strategies - Key Question 3

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. exp Hepatitis B/ or exp Hepatitis B virus/ or hepatitis b.mp.
2. exp Mass Screening/
3. screen$.mp.
4. Risk Assessment/ or risk assessment.mp.
5. Program Evaluation/
6. Prognosis/
7. prognos$.mp.
8. “Sensitivity and Specificity”/
9. *“Community-Based Participatory Research”/
10. Community Health Services/ or Community Networks/
11. Statistics as Topic/ or Chi-Square Distribution/
12. (screen$ adj1 (strateg$ or method$ or algorithm$)).mp.
13. 2 or 3 or 12
14. 1 and 13
15. or/4-11
16. 14 and 15
17. limit 16 to english language
18. limit 16 to abstracts
19. 17 or 18
20. Pregnancy/
21. 19 not 20

PsycINFO
1. hepatitis b.mp. (752)
2. hbv.mp. (270)
3. 1 or 2 (795)
4. exp Screening Tests/ or exp Screening/ or screen$.mp. (63956)
5. 3 and 4 (133)

### Vaccination and Clinical Outcomes - Key Question 4

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. cirrhosis.mp. or Fibrosis/
2. morbidity.mp. or Morbidity/
3. Carcinoma, Hepatocellular/
4. Liver Cirrhosis/
5. “Quality of Life”/
6. mo.mp. or tm.fs.
7. or/1-6
8. hepatitis b vaccine.mp. or exp Hepatitis B Vaccines/
9. 7 and 8
10. limit 9 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
11. Pregnancy/
12. 10 not 11
13. limit 12 to english language
14. limit 12 to abstracts
15. 13 or 14

EBM Reviews - Cochrane Central Register of Controlled Trials
1. cirrhosis.mp. or Fibrosis/
2. morbidity.mp. or Morbidity/
3. Carcinoma, Hepatocellular/
4. Liver Cirrhosis/
5. “Quality of Life”/
6. mo.mp. or tm.fs.
7. or/1-6
8. hepatitis b vaccine.mp. or exp Hepatitis B Vaccines/
9. 7 and 8
10. Pregnancy/
11. 9 not 10

### Treatment – Key Questions 5, 6, 7

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hepatitis B/dt, th or Hepatitis B, Chronic/dt, th
2. Hepatitis B virus/de
3. (hepatitis b or hbv).mp.
4. th.fs.
5. 3 and 4
6. 1 or 2
7. 5 or 6
8. Pregnancy/
9. 7 not 8
10. limit 9 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
11. randomized controlled trial.mp. or exp Randomized Controlled Trial/
12. randomized controlled trial.pt.
13. controlled clinical trial.mp. or exp Controlled Clinical Trial/
14. controlled clinical trial.pt.
15. clinical trial.mp. or exp Clinical Trial/
16. clinical trial.pt.
17. Comparative Study/
18. or/11-17
19. limit 18 to humans
20. 10 and 19

EBM Reviews - Cochrane Central Register of Controlled Trials
1. Hepatitis B/dt, th or Hepatitis B, Chronic/dt, th
2. Hepatitis B virus/de
3. (hepatitis b or hbv).mp.
4. th.fs.
5. 3 and 4
6. 1 or 2
7. 5 or 6
8. Pregnancy/
9. 7 not 8
10. limit 9 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)

### Education or Counseling Supplemental Search – Key Question 7

PsycINFO
1. (“hepatitis b” or “hbv”).mp.
2. 1 and (education or counsel$ or behavior$).mp.
3. limit 2 to all journals
4. limit 3 to (human and english language)

### Harms of Treatment – Key Question 8

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hepatitis B/dt, th or Hepatitis B, Chronic/dt, th
2. Hepatitis B virus/de
3. (hepatitis b or hbv).mp.
4. th.fs.
5. 3 and 4
6. 1 or 2
7. 5 or 6
8. Pregnancy/
9. 7 not 8
10. limit 9 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
11. (ae or mo or po or to or ct).fs.
12. (adverse adj1 (effect$ or reaction$ or event$ or outcome$)).mp.
13. harm$.mp.
14. or/11-13
15. 10 and 14
16. 15 not (case series or case studies or editorial or comment).pt.
17. limit 16 to english language
18. limit 17 to abstracts
19. 17 or 18

### Improvement in Intermediate Outcome and Effect on Clinical Outcomes – Key Question 9

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hepatitis B/ or Hepatitis B, Chronic/ or Hepatitis B virus/ or hepatitis b.mp.
2. hbv.mp.
3. 1 or 2
4. Treatment Outcome/
5. 3 and 4
6. limit 5 to english language
7. limit 6 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
8. Pregnancy/
9. 7 not 8
10. 9 not (case series or case reports or editorial or comment).pt.
11. cirrhosis.mp. or Fibrosis/
12. morbidity.mp. or Morbidity/
13. Carcinoma, Hepatocellular/
14. Liver Cirrhosis/
15. “Quality of Life”/
16. mo.mp. or tm.fs.
17. or/11-16
18. 10 and 17

### Systematic Reviews – All Key Questions

EBM Reviews - Cochrane Database of Systematic Reviews
1. (hepatitis b or hbv).ti.
2. limit 1 to full systematic reviews
3. limit 1 to recently updated reviews
4. limit 1 to new reviews
5. or/2-4

Ovid MEDLINE(R) without Revisions
1. Hepatitis B virus/ or Hepatitis B/ or Hepatitis B, Chronic/ or hepatitis b.mp.
2. limit 1 to yr=“2008 -Current”
3. limit 2 to evidence based medicine reviews
4. meta-analysis.mp. or exp Meta-Analysis/
5. (cochrane or medline).tw.
6. search$.tw.
7. 4 or 5 or 6
8. “Review Literature as Topic”/ or systematic review.mp.
9. 7 or 8
10. 2 and 9
11. 3 or 10
12. limit 11 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
13. limit 12 to english language

## Appendix A2 Inclusion and Exclusion Criteria per Key Question

| Include | Exclude
Definition of Disease | Chronic HBV infection: detectable HBsAg in serum for >6 months | Acute HBV infection
Populations
KQs 1-3 | Nonpregnant adults (≥18 years of age) and adolescents (13 to <18 years of age) asymptomatic for HBV infection | Symptomatic patients, children and pregnant women, HIV(+) or HCV(+) persons or persons or other special populations, such as hemodialysis, transplant, and treatment failure populations
KQ 4 | Persons without evidence of HBV immunity or disease on screening
KQs 5-9 | Nonpregnant adults and adolescents with chronic HBV infection
Interventions
KQs 1, 2 | Screening
KQ 3 | Screening strategies | Lab test results
KQ 4 | Vaccination
KQs 5-9 | Antiviral treatments for treatment naïve patients (Note: FDA-approved treatments include: Interferon alpha 2b, Pegylated interferon alpha 2a, Lamivudine, Adefovir, Entecavir, Telbivudine, Tenofovir) Education or behavior change counseling | Non-FDA approved antiviral treatments, combination therapy
Comparators
KQs 1, 2 | No screening
KQ 4 | No vaccination
KQs 5-7 | No treatment. Also, for currently recommended first-line antiviral therapies, the comparator was older antiviral therapies.
KQ 3 | Other screening strategies
KQ 8 | No treatment. Also, for currently recommended first-line antiviral therapies, the comparator was older antiviral therapies.
Outcomes
KQ 2 | Labeling, anxiety, stigma Harms from liver biopsy Side effects
KQ 3 | Measures of predictive validity
KQ 4 | Disease prevention
KQ 5 | [underlined: Intermediate outcomes]: Virologic improvement Histologic improvement HBeAg clearance | Drug resistance Development of mutations or antibodies to drugs
KQs 1, 6, 7, 9 | [underlined: Final outcomes]: Mortality Cirrhosis Hepatocellular cancer Quality of life Disease transmission
KQ 8 | Harms from antiviral medications Withdrawals due to adverse events
Setting | Primary care and primary care referable settings, e.g., correctional settings and community care settings serving injection drug users/men who have sex with men/sexually transmitted disease populations United States and countries with similar HBV prevalence, except for antiviral therapies (all countries)
Study Designs
KQ 1 | Randomized controlled trials and controlled observational studies | Uncontrolled studies
KQs 2, 8 | Randomized controlled trials and controlled observational studies; or large, uncontrolled observational studies with long-term followup. Also for KQ 8, head-to-head trials for currently recommended first-line antiviral therapies. | Very small uncontrolled studies; case studies
KQ 3 | Studies assessing predictive validity of screening strategies
KQs 4-7 | Randomized, placebo-controlled trials. Also, head-to-head trials for currently recommended first-line antiviral therapies.
KQ 9 | Cohort studies examining the association between intermediate and clinical outcomes after antiviral treatment

Abbreviations: HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCV = hepatitis C virus; FDA = U.S. Food and Drug Administration; HIV = human immunodeficiency virus; KQ = key question.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

** Other sources include reference lists of relevant articles.

† Some studies are included for more than one key question.

## Appendix A4 Excluded Studies

### Wrong Population

Failure of specific immunotherapy in fulminant type B hepatitis. Ann Intern Med. 1977;86(3):272-7. [pmid: 320929].
Implementation of newborn hepatitis B vaccination--worldwide, 2006. MMWR Morb Mortal Wkly Rep. 2008;57(46):1249-52. [pmid: 19023261].
Akhter MN, Stout C, Twiehaus JM. Hepatitis B screening and vaccination in a facility for the mentally retarded. Mo Med. 1985;82(7):345. [pmid: 4021987].
Arulrajan A, Tyrie C, Phillips K, O'Connell S. Hepatitis B screening and immunization for people with a mental handicap in Southampton: Costs and benefits. J Intellect Disabil Res. 1992;36(3):259-64. [pmid: 1535820].
Bayliss MS, Gandek B, Bungay KM, Sugano D, Hsu MA, Ware JE Jr. A questionnaire to assess the generic and disease-specific health outcomes of patients with chronic hepatitis C. Qual Life Res. 1998;7(1):39-55. [pmid: 9481150].
Campos-Outcalt D. Hepatitis B virus screening in a high-risk college population. J Am Coll Health. 1985;34(3):120-2. [pmid: 4086715].
Carreno V, Marcellin P, Hadziyannis S, Salmeron J, Diago M, Kitis GE, et al. Retreatment of chronic hepatitis B e antigen-positive patients with recombinant interferon alfa-2a. The European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. 1999;30(1):277-82. [pmid: 10385667].
Cavenaugh JS, Awi D, Mendy M, Hill AVS, Whittle H, McConkey SJ. Partially randomized, non-blinded trial of DNA and MVA therapeutic Vaccines based on hepatitis B virus surface protein for chronic HBV infection. PLoS ONE. 2011;6(2):e14626. [pmid: 21347224].
Chang MH. Impact of hepatitis B vaccination on hepatitis B disease and nucleic acid testing in high-prevalence populations. J Clin Virol. Suppl 1. 2006;36:S45-50. [pmid: 16831693].
Chen DK, Yim C, O'Rourke K, Krajden M, Wong DK, Heathcote EJ. Long-term follow-up of a randomized trial of interferon therapy for chronic hepatitis B in a predominantly homosexual male population. J Hepatol. 1999;30(4):557-63. [pmid: 10207795].
Chien RN, Lin CH, Liaw YF. The effect of lamivudine therapy in hepatic decompensation during acute exacerbation of chronic hepatitis B. J Hepatol. 2003;38(3):322-7. [pmid: 12586298].
Chou R, Wasson N. Blood tests to diagnose fibrosis or cirrhosis in patients with chronic hepatitis C virus infection: a systematic review. Ann Intern Med. 2013;158(11):807-20. [pmid: 23732714].
De Maria E, Gabrielli GB, Casaril M, Galiotto M, Dagradi R, Squarzoni S, et al. Chronic viral hepatitis and interferon treatment: clinical experience in a series of 200 Italian patients. J Chemother. 1998;10(2):173-5. [pmid: 9603650].
Denburg A, Rashid M, Brophy J, Curtis T, Malloy P, Audley J, et al. Initial health screening results for Karen refugees: a retrospective review. Can Commun Dis Rep. 2007;33(13):16-22. [pmid: 18161207].
Dhillon S, Moore C, Li SD, Aziz A, Kakar A, Dosanjh A, et al. Efficacy of high-dose intra-dermal hepatitis B virus Vaccine in previous vaccination non-responders with chronic liver disease. Dig Dis Sci. 2012;57(1):215-20. [pmid: 22160636].
Dore GJ, Cooper DA, Pozniak AL, DeJesus E, Zhong L, Miller MD, et al. Efficacy of tenofovir disoproxil fumarate in antiretroviral therapy-naive and -experienced patients coinfected with HIV-1 and hepatitis B virus. J Infect Dis. 2004;189(7):1185-92. [pmid: 15031786].
Etemadi J, Somi MH, Ardalan MR, Hashemi SSR, Soltani GG, Shoja MM. Prevalence and risk factors of hepatitis B infection among hemodialysis patients in Tabriz: a multicenter report. Saudi J Kidney Dis Transpl. 2012;23(3):609-13. [pmid: 22569457].
Finelli L, Miller JT, Tokars JI, Alter MJ, Arduino MJ. National surveillance of dialysis-associated diseases in the United States, 2002. Semin Dial. 2005;18(1):52-61. [pmid: 15663766].
Fisher A, Musini VM, Bassett K. Antiviral treatments for lamivudine-resistant chronic hepatitis B adult patients. Cochrane Database Syst Rev. 2009;(4).
Flink HJ, Hansen BE, Heathcote EJ, Feinman SV, Simsek H, Karayalcin S, et al. Successful treatment with peginterferon alfa-2b of HBeAg-positive HBV non-responders to standard interferon or lamivudine. Am J Gastroenterol. 2006;101(11):2523-9. [pmid: 17029610].
Fowler A, Sudhanva M, Zuckerman M. Hepatitis B screening in HIV-infected individuals. AIDS. 2005;19(12):1338-9. [pmid: 16052098].
Gilson RJ, Chopra KB, Newell AM, Murray-Lyon IM, Nelson MR, Rice SJ, et al. A placebo-controlled phase I/II study of adefovir dipivoxil in patients with chronic hepatitis B virus infection. J Viral Hepat. 1999;6(5):387-95. [pmid: 10607255].
Guennoc X, Narbonne V, Jousse-Joulin S, Devauchelle-Pensec V, Dougados M, Daures JP, et al. Is screening for hepatitis B and hepatitis C useful in patients with recent-onset polyarthritis? The ESPOIR cohort study. J Rheumatol. 2009;36(7):1407-13. [pmid: 19531755].
Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, Chang TT, Kitis G, Rizzetto M, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B. N Engl J Med. 2005;352(26):2673-81. [pmid: 15987916].
Hashimoto Y, Suzuki F, Hirakawa M, Kawamura Y, Yatsuji H, Sezaki H, et al. Clinical and virological effects of long-term (over 5 years) lamivudine therapy. J Med Virol. 2010;82(4):684-91. [pmid: 20166170].
Hezode C, Chevaliez S, Bouvier-Alias M, Roudot-Thoraval F, Brillet R, Zafrani ES, et al. Efficacy and safety of adefovir dipivoxil 20 mg daily in HBeAg-positive patients with lamivudine-resistant hepatitis B virus and a suboptimal virological response to adefovir dipivoxil 10 mg daily. J Hepatol. 2007;46(5):791-6. [pmid: 17321635].
Idilman R, Cinar K, Seven G, Bozkus Y, Elhan A, Bozdayi M, et al. Hepatitis B surface antigen seroconversion is associated with favourable long-term clinical outcomes during lamivudine treatment in HBeAg-negative chronic hepatitis B patients. J Viral Hepat. 2012;19(3):220-6. [pmid: 22329377].
Jonas MM, Little NR, Gardner SD, Alonso EM, Alvarez F, Areias J, et al. Long-term lamivudine treatment of children with chronic hepatitis B: Durability of therapeutic responses and safety. J Viral Hepat. 2008;15(1):20-7. [pmid: 18088241].
Kanda Y, Shigeno K, Kinoshita N, Nakao K, Yano M, Matsuo H. Sudden hearing loss associated with interferon. Lancet. 1994;343(8906):1134-5. [pmid: 7910234].
Kim JH, Yim HJ, Jung ES, Jung YK, Seo YS, Yeon JE, et al. Virologic and biochemical responses to clevudine in patients with chronic HBV infection-associated cirrhosis: data at week 48. J Viral Hepat. 2011;18(4):287-93. [pmid: 20367793].
Kim WR, Terrault NA, Pedersen RA, Therneau TM, Edwards E, Hindman AA, et al. Trends in waiting list registration for liver transplantation for viral hepatitis in the United States. Gastroenterology. 2009;137(5):1680-6. [pmid: 19632234].
Kumar M, Satapathy S, Monga R, Das K, Hissar S, Pande C, et al. A randomized controlled trial of lamivudine to treat acute hepatitis B. Hepatology. 2007;45(1):97-101. [pmid: 17187417].
Kundu SS, Kundu AK, Pal NK. Interferon-alpha in the treatment of acute prolonged hepatitis B virus infection. J Assoc Physicians India. 2000;48(7):671-3. [pmid: 11273498].
Manegold C, Hannoun C, Wywiol A, Dietrich M, Polywka S, Chiwakata CB, et al. Reactivation of hepatitis B virus replication accompanied by acute hepatitis in patients receiving highly active antiretroviral therapy. Clin Infect Dis. 2001;32(1):144-8. [pmid: 11118394].
Manolakopoulos S, Karatapanis S, Elefsiniotis J, Mathou N, Vlachogiannakos J, Iliadou E, et al. Clinical course of lamivudine monotherapy in patients with decompensated cirrhosis due to HBeAg negative chronic HBV infection. Am J Gastroenterol. 2004;99(1):57-63. [pmid: 14687142].
Matsue K, Aoki T, Odawara J, Fujiwara H, Iwama Ki, Kimura Si, et al. High risk of hepatitis B-virus reactivation after hematopoietic cell transplantation in hepatitis B core antibody-positive patients. Eur J Haematol. 2009;83(4):357-64. [pmid: 19508685].
Mathew JL, El Dib R, Mathew PJ, Boxall EH, Brok J. Hepatitis B immunization in persons not previously exposed to hepatitis B or with unknown exposure. Cochrane Database Syst Rev. 2009;(1).
Matthews GV, Avihingsanon A, Lewin SR, Amin J, Rerknimitr R, Petcharapirat P, et al. A randomized trial of combination hepatitis B therapy in HIV/HBV coinfected antiretroviral naive individuals in Thailand. Hepatology. 2008;48(4):1062-9. [pmid: 18697216].
Mazzella G, Accogli E, Sottili S, Festi D, Orsini M, Salzetta A, et al. Alpha interferon treatment may prevent hepatocellular carcinoma in HCV-related liver cirrhosis. J Hepatol. 1996;24(2):141-7. [pmid: 8907566].
McCaughan G, Angus P, Bowden S, Shaw T, Breschkin A, Sheil R, et al. Retransplantation for precore mutant-related chronic hepatitis B infection: prolonged survival in a patient receiving sequential ganciclovir/famciclovir therapy. Liver Transpl Surg. 1996;2(6):472-4. [pmid: 9346695].
McDonald EM, Mann AH, Thomas HC. Interferons as mediators of psychiatric morbidity. An investigation in a trial of recombinant alpha-interferon in hepatitis-B carriers. Lancet. 1987;2(8569):1175-8. [pmid: 2890808].
McGory RW, Ishitani MB, Oliveira WM, Stevenson WC, Dickson RC, Caldwell SH, et al. Effects of fialuridine on hepatitis B immune globulin pharmacokinetics following orthotopic liver transplant for chronic hepatitis B viral-induced cirrhosis. Transplant Proc. 1995;27(1):1213-4. [pmid: 7878854].
McPhee SJ, Nguyen T, Euler GL, Mock J, Wong C, Lam T, et al. Successful promotion of hepatitis B vaccinations among Vietnamese-American children ages 3 to 18: results of a controlled trial. Pediatrics. 2003;111(6 Pt 1):1278-88. [pmid: 12777542].
Medeiros RH, Figueiredo AEP, Poli-de-Figueiredo CE, d'Avila DO, de los Santos CA. Low response to intradermal hepatitis B vaccination in incident hemodialysis patients. J Bras Nefrol. 2011;33(1):45-9. [pmid: 21541462].
Mederacke I, Yurdaydin C, Groshennig A, Erhardt A, Cakaloglu Y, Yalcin K, et al. Renal function during treatment with adefovir plus peginterferon alfa-2a vs either drug alone in hepatitis B/D co-infection. J Viral Hepat. 2012;19(6):387-95. [pmid: 22571900].
Micozkadioglu H, Zumrutdal A, Torun D, Sezer S, Ozdemir FN, Haberal M. Low dose intradermal vaccination is superior to high dose intramuscular vaccination for hepatitis B in unresponsive hemodialysis patients. Ren Fail. 2007;29(3):285-8. [pmid: 17497441].
Mittal SK, Rao S, Kumari S, Aggarwal V, Prakash C, Thirupuram S. Simultaneous administration of hepatitis B Vaccine with other E.P.I. Vaccines. Indian J Pediatr. 1994;61(2):183-8. [pmid: 7927617].
Mitwalli A. Responsiveness to hepatitis B Vaccine in immunocompromised patients by doubling the dose scheduling. Nephron. 1996;73(3):417-20. [pmid: 8832600].
Mok Q, Underhill G, Wonke B, Aldouri M, Kelsey M, Jefferies D. Intradermal hepatitis B Vaccine in thalassaemia and sickle cell disease. Arch Dis Child. 1989;64(4):535-40. [pmid: 2526622].
Molina J, Bartolome J, Moraleda G, Ruiz-Moreno M, Rua MJ, Moreno A, et al. Persistence of hepatitis B virus DNA after reduction of viral replication in serum and liver. J Med Virol. 1992;38(1):11-5. [pmid: 1383416].
Monteon FJ, Contreras AM, Espinoza L, Vazquez G, Aguilar S, Cueva L. Interferon alfa-2b in renal transplant recipients with viral chronic hepatitis: a pilot study. Transplant Proc. 1996;28(6):3306-8. [pmid: 8962284].
Moses SE, Lim ZY, Sudhanva M, Devereux S, Ho AYL, Pagliuca A, et al. Lamivudine prophylaxis and treatment of hepatitis B Virus-exposed recipients receiving reduced intensity conditioning hematopoietic stem cell transplants with alemtuzumab. J Med Virol. 2006;78(12):1560-3. [pmid: 17063522].
Mu SC, Wang GM, Jow GM, Chen BF. Impact of universal vaccination on intrafamilial transmission of hepatitis B virus. J Med Virol. 2011;83(5):783-90. [pmid: 21360549].
Nagamatsu H, Itano S, Nagaoka S, Akiyoshi J, Matsugaki S, Kurogi J, et al. Prophylactic lamivudine administration prevents exacerbation of liver damage in HBe antigen positive patients with hepatocellular carcinoma undergoing transhepatic arterial infusion chemotherapy. Am J Gastroenterol. 2004;99(12):2369-75. [pmid: 15571585].
Nam SW, Bae SH, Lee SW, Kim YS, Kang SB, Choi JY, et al. Short-term overlap lamivudine treatment with adefovir dipivoxil in patients with lamivudine-resistant chronic hepatitis B. World J Gastroenterol. 2008;14(11):1781-4. [pmid: 18350610].
Nardiello S, Gargiulo M, Pizzella T, Digilio L, Di Ottavio L, Galanti B. Relation of changes in hepatitis B virus replication markers to the outcome of interferon treatment in patients with chronic hepatitis. J Chemother. 1992;4(2):95-8. [pmid: 1629752].
Narkewicz MR, Smith D, Silverman A, Vierling J, Sokol RJ. Clearance of chronic hepatitis B virus infection in young children after alpha interferon treatment. J Pediatr. 1995;127(5):815-8. [pmid: 7472844].
Neudorf-Grauss R, Bujanover Y, Dinari G, Broide E, Neveh Y, Zahavi I, et al. Chronic hepatitis B virus in children in Israel: clinical and epidemiological characteristics and response to interferon therapy. Isr Med Assoc J. 2000;2(2):164-8. [pmid: 10804945].
Niederhauser C, Mansouri Taleghani B, Graziani M, Stolz M, Tinguely C, Schneider P. Blood donor screening: how to decrease the risk of transfusion-transmitted hepatitis B virus?. Swiss Med Wkly. 2008;138(9-10):134-41. [pmid: 18330733].
Nikolaidis N, Vassiliadis T, Giouleme O, Tziomalos K, Grammatikos N, Patsiaoura K, et al. Effect of lamivudine treatment in patients with decompensated cirrhosis due to anti-HBe positive/HBeAg-negative chronic hepatitis B. Clin Transplant. 2005;19(3):321-6. [pmid: 15877792].
Novack L, Sarov B, Goldman-Levi R, Yahalom V, Safi J, Soliman H, et al. Impact of pooling on accuracy of hepatitis B virus surface antigen screening of blood donations. Trans R Soc Trop Med Hyg. 2008;102(8):787-92. [pmid: 18486172].
Ozgenc F, Arikan C, Sertoz RY, Nart D, Aydogdu S, Yagci RV. Effect of long-term lamivudine in chronic hepatitis B virus-infected children. Antivir Ther. 2004;9(5):729-32. [pmid: 15535410].
Pallier C, Rodriguez C, Brillet R, Nordmann P, Hezode C, Pawlotsky JM. Complex dynamics of hepatitis B virus resistance to adefovir. Hepatology. 2009;49(1):50-9. [pmid: 19065672].
Pan CQ, Hu KQ, Yu AS, Chen W, Bunchorntavakul C, Reddy KR. Response to tenofovir monotherapy in chronic hepatitis B patients with prior suboptimal response to entecavir. J Viral Hepat. 2012;19(3):213-9. [pmid: 22329376].
Papaevangelou G, Roumeliotou-Karayannis A, Tassopoulos N, Kolaitis N, Contoyannis P, Krugman S. Post-exposure hepatitis B vaccination of sexual partners of acute viral hepatitis patients. The Journal of infection. 1983;7(1):63-7. [pmid: 6371152].
Park JW, Kim HS, Seo DD, Jang JS, Shin WG, Kim KH, et al. Long-term efficacy of entecavir in adefovir-refractory chronic hepatitis B patients with prior lamivudine resistance. J Viral Hepat. 2011;18(10):e475-81. [pmid: 21914066].
Park SJ, Paik SW, Choi MS, Lee JH, Koh KC, Kim SJ, et al. Is lamivudine with 1-week HBlg as effective as long-term high-dose HBlg in HBV prophylaxis after liver transplantation?. Transplant Proc. 2002;34(4):1252-4. [pmid: 12072331].
Patterson SJ, George J, Strasser SI, Lee AU, Sievert W, Nicoll AJ, et al. Tenofovir disoproxil fumarate rescue therapy following failure of both lamivudine and adefovir dipivoxil in chronic hepatitis B. Gut. 2011;60(2):247-54. [pmid: 21036792].
Pei SN, Chen CH, Lee CM, Wang MC, Ma MC, Hu TH, et al. Reactivation of hepatitis B virus following rituximab-based regimens: a serious complication in both HBsAg-positive and HBsAg-negative patients. Ann Hematol. 2010;89(3):255-62. [pmid: 19697028].
Perrillo RP, Wright T, Rakela J, Levy G, Schiff E, Gish R, et al. A multicenter United States-Canadian trial to assess lamivudine monotherapy before and after liver transplantation for chronic hepatitis B. Hepatology. 2001;33(2):424-32. [pmid: 11172345].
Perz JF, Elm JL Jr., Fiore AE, Huggler JI, Kuhnert WL, Effler PV. Near elimination of hepatitis B virus infections among Hawaii elementary school children after universal infant hepatitis B vaccination. Pediatrics. 2006;118(4):1403-8. [pmid: 17015529].
Porres JC, Mora I, Gutiez J, Bartolome J, Quiroga JA, Bas C, et al. Antiviral effect of recombinant gamma interferon in chronic hepatitis B virus infection: a pilot study. HepatoGastroenterology. 1988;35(1):5-9. [pmid: 2452123].
Preziati D, La Rosa L, Covini G, Marcelli R, Rescalli S, Persani L, et al. Autoimmunity and thyroid function in patients with chronic active hepatitis treated with recombinant interferon alpha-2a. Eur J Endocrinol. 1995;132(5):587-93. [pmid: 7749499].
Qin H, Li H, Xing M, Wu C, Li G, Song J. Nutritional support treatment for severe chronic hepatitis and posthepatitic cirrhosis. J Huazhong Univ Sci Technolog Med Sci. 2006;26(2):217-20. [pmid: 16850751].
Roumeliotou-Karayannis A, Papaevangelou G, Tassopoulos N, Richardson SC, Krugman S. Post-exposure active immunoprophylaxis of spouses of acute viral hepatitis B patients. Vaccine. 1985;3(1):31-4. [pmid: 3890398].
Schiff ER, Dienstag JL, Karayalcin S, Grimm IS, Perrillo RP, Husa P, et al. Lamivudine and 24 weeks of lamivudine/interferon combination therapy for hepatitis B e antigen-positive chronic hepatitis B in interferon nonresponders. J Hepatol. 2003;38(6):818-26. [pmid: 12763376].
Schmilovitz-Weiss H, Ben-Ari Z, Sikuler E, Zuckerman E, Sbeit W, Ackerman Z, et al. Lamivudine treatment for acute severe hepatitis B: a pilot study. [Erratum appears in Liver Int. 2005; 25(1):196]. Liver Int. 2004;24(6):547-51. [pmid: 15566503].
Sherman M, Yurdaydin C, Sollano J, Silva M, Liaw YF, Cianciara J, et al. Entecavir for treatment of lamivudine-refractory, HBeAg-positive chronic hepatitis B. Gastroenterology. 2006;130(7):2039-49. [pmid: 16762627].
Summers PR, Biswas MK, Pastorek JG 2nd, Pernoll ML, Smith LG, Bean BE. The pregnant hepatitis B carrier: evidence favoring comprehensive antepartum screening. Obstet Gynecol. 1987;69(5):701-4. [pmid: 3574797].
Sun HC, Tang ZY, Wang L, Qin LX, Ma ZC, Ye QH, et al. Postoperative interferon alpha treatment postponed recurrence and improved overall survival in patients after curative resection of HBV-related hepatocellular carcinoma: a randomized clinical trial. J Cancer Res Clin Oncol. 2006;132(7):458-65. [pmid: 16557381].
Toccaceli F, Rosati S, Scuderi M, Iacomi F, Picconi R, Laghi V. Leukocyte and platelet lowering by some interferon types during viral hepatitis treatment. HepatoGastroenterology. 1998;45(23):1748-52. [pmid: 9840140].
Tsubota A, Arase Y, Suzuki Y, Suzuki F, Hosaka T, Akuta N, et al. Benefit of lamivudine therapy and factors associated with clinical outcome in spontaneous severe acute exacerbation of chronic hepatitis B virus infection. Intervirology. 2004;47(6):335-41. [pmid: 15564745].
Tsubota A, Arase Y, Suzuki Y, Suzuki F, Sezaki H, Hosaka T, et al. Lamivudine monotherapy for spontaneous severe acute exacerbation of chronic hepatitis B. J Gastroenterol Hepatol. 2005;20(3):426-32. [pmid: 15740488].
van Bommel F, de Man RA, Wedemeyer H, Deterding K, Petersen J, Buggisch P, et al. Long-term efficacy of tenofovir monotherapy for hepatitis B virus-monoinfected patients after failure of nucleoside/nucleotide analogues. Hepatology. 2010;51(1):73-80. [pmid: 19998272].
van Bommel F, Zollner B, Sarrazin C, Spengler U, Huppe D, Moller B, et al. Tenofovir for patients with lamivudine-resistant hepatitis B virus (HBV) infection and high HBV DNA level during adefovir therapy. Hepatology. 2006;44(2):318-25. [pmid: 16871563].
van der Eijk AA, Hansen BE, Niesters HGM, Janssen HLA, van de Ende M, Schalm SW, et al. Viral dynamics during tenofovir therapy in patients infected with lamivudine-resistant hepatitis B virus mutants. J Viral Hepat. 2005;12(4):364-72. [pmid: 15985006].
Van Thiel DH, Friedlander L, Kania RJ, Molloy PJ, Hassanein T, Wahlstrom E, et al. Lamivudine treatment of advanced and decompensated liver disease due to hepatitis B. HepatoGastroenterology. 1997;44(15):808-12. [pmid: 9222695].
Vassilopoulos D, Apostolopoulou A, Hadziyannis E, Papatheodoridis GV, Manolakopoulos S, Koskinas J, et al. Long-term safety of anti-TNF treatment in patients with rheumatic diseases and chronic or resolved hepatitis B virus infection. Ann Rheum Dis. 2010;69(7):1352-5. [pmid: 20472596].
Wong DK, Yim C, Naylor CD, Chen E, Sherman M, Vas S, et al. Interferon alfa treatment of chronic hepatitis B: randomized trial in a predominantly homosexual male population. Gastroenterology. 1995;108(1):165-71. [pmid: 7806038].
Wong VWS, Wong GLH, Tsang SWC, Hui AY, Chim AML, Yiu KKL, et al. Long-term follow-up of lamivudine treatment in patients with severe acute exacerbation of hepatitis B e antigen (HBeAg)-positive chronic hepatitis B. Antivir Ther. 2008;13(4):571-9. [pmid: 18672536].
Yagci M, Ozkurt ZN, Yegin ZA, Aki Z, Sucak GT, Haznedar R. Hepatitus B virus reactivation in HBV-DNA negative and positive patients with hematological malignancies. Hematology. 2010;15(4):240-4. [pmid: 20670484].
Yao FY, Bass NM. Lamivudine treatment in patients with severely decompensated cirrhosis due to replicating hepatitis B infection. J Hepatol. 2000;33(2):301-7. [pmid: 10952248].
Yildiz O, Aygen B, Demirturk N, Demirdal T, Inan D, Yildirmak T, et al. Lamivudine resistance mutations in patients infected with hepatitis B virus genotype D. World J Gastroenterol. 2011;17(45):4987-92. [pmid: 22174548].
Yu JW, Sun LJ, Zhao YH, Kang P, Li SC. The study of efficacy of lamivudine in patients with severe acute hepatitis B. Dig Dis Sci. 2010;55(3):775-83. [pmid: 19957031].
Zhang CH, Xu GL, Jia WD, Li JS, Ma JL, Ge YS. Effects of interferon treatment on development and progression of hepatocellular carcinoma in patients with chronic virus infection: a meta-analysis of randomized controlled trials. Int J Cancer. 2011;129(5):1254-64. [pmid: 21710498].

### Wrong Intervention

Steroids in chronic B-hepatitis. A randomized, double-blind, multinational trial on the effect of low-dose, long-term treatment on survival. A trial group of the European Association for the Study of the Liver. Liver. 1986;6(4):227-32. [pmid: 2877383].
Akarca US, Ersoz G, Gunsar F, Karasu Z, Saritas E, Yuce G, et al. Interferon-lamivudine combination is no better than lamivudine alone in anti-HBe-positive chronic hepatitis B. Antivir Ther. 2004;9(3):325-34. [pmid: 15259895].
Alberti A, Fattovich G, Pontisso P, Brollo L, Belussi F, Ruol A. Interferon treatment of anti-HBe positive and HBV DNA positive chronic hepatitis B. Chemioterapia. 1988;7(3):15-9. [pmid: 3073869].
Alexander GJ, Brahm J, Fagan EA, Smith HM, Daniels HM, Eddleston AL, et al. Loss of HBsAg with interferon therapy in chronic hepatitis B virus infection. Lancet. 1987;2(8550):66-9. [pmid: 2885573].
Alexander GJ, Fagan EA, Guarner P, Rolando N, Brahm J, Eddleston AL, et al. A controlled trial of 6 months thrice weekly lymphoblastoid interferon versus no therapy in chronic hepatitis B virus infection. A preliminary analysis of the first 32 patients. J Hepatol. 1986;3(2):S183-S8. [pmid: 3298406].
Alexander GJ, Fagan EA, Hegarty JE, Yeo J, Eddleston AL, Williams R. Controlled clinical trial of acyclovir in chronic hepatitis B virus infection. J Med Virol. 1987;21(1):81-7. [pmid: 3540212].
Ambrosch F, Andre FE, Delem A, D'Hondt E, Jonas S, Kunz C, et al. Simultaneous vaccination against hepatitis A and B: results of a controlled study. Vaccine. Suppl 1. 1992;10:S142-5. [pmid: 1335647].
Anderson MG, Harrison TJ, Alexander G, Zuckerman AJ, Murray-Lyon IM. Randomised controlled trial of lymphoblastoid interferon for chronic active hepatitis B. Gut. 1987;28(5):619-22. [pmid: 3297940].
Anderson MG, Harrison TJ, Alexander GJ, Zuckerman AJ, Murray-Lyon IM. Randomised controlled trial of lymphoblastoid interferon for chronic active hepatitis B. J Hepatol. 1986;3(2).
Badamchian M, Goldstein AL, Sztein MB. Immune and neuroendocrine modulation with thymosins: current status of recent clinical trials in the United States. Int J Neurosci. 1990;51(3-4):365-7. [pmid: 2279903].
Bahrami H, Daryani NE, Haghpanah B, Moayyeri A, Moghadam KF, Mirmomen S, et al. Effects of indomethacin on viral replication markers in asymptomatic carriers of hepatitis B: a randomized, placebo-controlled trial. Am J Gastroenterol. 2005;100(4):856-61. [pmid: 15784032].
Barbara L, Mazzella G, Baraldini M, Gasbarrini G, Giungi F, Malavolti M, et al. A randomised controlled trial with human lymphoblastoid interferon vs no treatment in chronic hepatitis B virus infection. Preliminary results. J Hepatol. 1986;3(2).
Barbaro G, Zechini F, Pellicelli AM, Francavilla R, Scotto G, Bacca D, et al. Long-term efficacy of interferon alpha-2b and lamivudine in combination compared to lamivudine monotherapy in patients with chronic hepatitis B. An Italian multicenter, randomized trial. J Hepatol. 2001;35(3):406-11. [pmid: 11592603].
Bassendine MF, Chadwick RG, Salmeron J, Shipton U, Thomas HC, Sherlock S. Adenine arabinoside therapy in HBsAg-positive chronic liver disease: a controlled study. Gastroenterology. 1981;80(5 pt 1):1016-22. [pmid: 7009310].
Beasley RP, Hwang LY, Lin CC, Chien CS. Hepatocellular carcinoma and hepatitis B virus. A prospective study of 22 707 men in Taiwan. Lancet. 1981;2(8256):1129-33. [pmid: 6118576].
Benvegnu L, Chemello L, Noventa F, Fattovich G, Pontisso P, Alberti A. Retrospective analysis of the effect of interferon therapy on the clinical outcome of patients with viral cirrhosis. Cancer. 1998;83(5):901-9. [pmid: 9731893].
Berk L, Schalm SW, de Man RA, Heytink RA, Berthelot P, Brechot C, et al. Failure of acyclovir to enhance the antiviral effect of alpha lymphoblastoid interferon on HBe-seroconversion in chronic hepatitis B. A multi-centre randomized controlled trial. J Hepatol. 1992;14(2-3):305-9. [pmid: 1500694].
Bissett J, Eisenberg M, Gregory P, Robinson WS, Merigan TC. Recombinant fibroblast interferon and immune interferon for treating chronic hepatitis B virus infection: patients' tolerance and the effect on viral markers. J Infect Dis. 1988;157(5):1076-80. [pmid: 3129521].
Blum AL, Berthet P, Doelle W, Goebell H, Kortum K, Pelloni S, et al. Treatment of acute viral hepatitis with (+)-cyanidanol-3. Lancet. 1977;2(8049):1153-5. [pmid: 73062].
Bodenheimer HC Jr., Schaffner F, Vernace S, Hirschman SZ, Goldberg JD, Chalmers T. Randomized controlled trial of quinacrine for the treatment of HBsAg-positive chronic hepatitis. Hepatology. 1983;3(6):936-8. [pmid: 6354904].
Brissot P, Jacquelinet C, Jouanolle H, David V, Guyader D, Gueguen M, et al. Short-term prednisolone followed by recombinant human alpha-interferon alone or combined with adenine-arabinoside in chronic hepatitis B. A prospective and randomized trial. J Hepatol. 1991;12(2):181-9. [pmid: 2050997].
Brook MG, Chan G, Yap I, Karayiannis P, Lever AM, Jacyna M, et al. Randomised controlled trial of lymphoblastoid interferon alfa in Europid men with chronic hepatitis B virus infection. BMJ. 1989;299(6700):652-6. [pmid: 2508850].
Brook MG, Main J, Yap I, Chan G, Karayiannis P, Crossey M, et al. Short report: prednisolone withdrawal followed by lymphoblastoid interferon in the therapy of adult patients with presumed childhood-acquired chronic hepatitis B virus infection. Aliment Pharmacol Ther. 1993;7(3):331-6. [pmid: 8364139].
Brook MG, McDonald JA, Karayiannis P, Caruso L, Forster G, Harris JR, et al. Randomised controlled trial of interferon alfa 2A (rbe) (Roferon-A) for the treatment of chronic hepatitis B virus (HBV) infection: factors that influence response. Gut. 1989;30(8):1116-22. [pmid: 2670693].
Capalbo M, Palmisano L, Bonino F, Pellas C, Maset J. Intramuscular natural beta interferon in the treatment of chronic hepatitis B: a multicentre trial. Italian Hepatitis B Study Group. Ital J Gastroenterol. 1994;26(5):238-41. [pmid: 7919465].
Carreno V, Moreno A, Galiana F, Bartolome FJ. Alpha- and gamma-interferon versus alpha-interferon alone in chronic hepatitis B. A randomized controlled study. J Hepatol. 1993;17(3):321-5. [pmid: 8315260].
Carreno V, Porres JC, Mora I, Gutiez J, Quiroga JA, Ramon y Cajal S, et al. A controlled study of treatment with recombinant interferon alpha in chronic hepatitis B virus infection: induction and maintenance schedules. Antiviral Res. 1987;8(3):125-37. [pmid: 3501274].
Caselmann WH, Eisenburg J, Hofschneider PH, Koshy R. Beta- and gamma-interferon in chronic active hepatitis B. A pilot trial of short-term combination therapy. Gastroenterology. 1989;96(2 Pt 1):449-55. [pmid: 2492011].
Chan HL, Heathcote EJ, Marcellin P, Lai CL, Cho M, Moon YM, et al. Treatment of hepatitis B e antigen positive chronic hepatitis with telbivudine or adefovir: a randomized trial. Ann Intern Med. 2007;147(11):745-54. [pmid: 17909201].
Chan HL, Hui AY, Wong VW, Chim AM, Wong ML, Sung JJ. Long-term follow-up of peginterferon and lamivudine combination treatment in HBeAg-positive chronic hepatitis B. Hepatology. 2005;41(6):1357-64. [pmid: 15880608].
Chan HL, Leung NW, Hui AY, Wong VW, Liew CT, Chim AM, et al. A randomized, controlled trial of combination therapy for chronic hepatitis B: comparing pegylated interferon-alpha2b and lamivudine with lamivudine alone. Ann Intern Med. 2005;142(4):240-50. [pmid: 15710957].
Chan HLY, Chen YC, Gane EJ, Sarin SK, Suh DJ, Piratvisuth T, et al. Randomized clinical trial: efficacy and safety of telbivudine and lamivudine in treatment-naive patients with HBV-related decompensated cirrhosis. J Viral Hepat. 2012;19(10):732-43. [pmid: 22967105].
Chan HLY, Wong VWS, Chim AML, Choi PCL, Chan HY, Hui AY, et al. Virological response to different combination regimes of peginterferon alpha-2b and lamivudine in hepatitis B e antigen positive chronic hepatitis B. Antivir Ther. 2007;12(5):815-23. [pmid: 17713165].
Chen CJ, Yang HI, Su J, Jen CL, You SL, Lu SN, et al. Risk of hepatocellular carcinoma across a biological gradient of serum hepatitis B virus DNA level. JAMA. 2006;295(1):65-73. [pmid: 16391218].
Chung HT, Lok AS, Lai CL. Re-evaluation of alpha-interferon treatment of chronic hepatitis B using polymerase chain reaction. J Hepatol. 1993;17(2):208-14. [pmid: 8445234].
Cohen M. The efficacy of a peptide-nucleic acid solution (Reticulose) for the treatment of hepatitis A and hepatitis B--a preliminary controlled human clinical trial. J R Soc Health. 1992;112(6):266-70. [pmid: 1469671].
Combarnous F, Fouque D, Chossegros P, Boulieu R, Laville M, Zech P. Neurologic side-effects of ganciclovir. Clin Nephrol. 1994;42(4):279-80. [pmid: 7834927].
Csatary LK, Telegdy L, Gergely P, Bodey B, Bakacs T. Preliminary report of a controlled trial of MTH-68/B virus Vaccine treatment in acute B and C hepatitis: a phase II study. Anti Cancer Res. 1998;18(2B):1279-82.
De Man RA, Schalm SW, Heijtink RA, Berk L, Den Ouden J, ten Kate FJ, et al. Long-term follow-up of antiviral combination therapy in chronic hepatitis B. Am J Med. 1988;85(2A):150-4. [pmid: 3044080].
Dehghan Nayeri N, Asadi Noghabi AA, Molaee S. The effect of telephone consultation on the quality of life of patients receiving interferon therapy: a quasi-experimental study. Telemed J E Health. 2012;18(6):459-63. [pmid: 22663759].
Di Bisceglie AM, Fong TL, Fried MW, Swain MG, Baker B, Korenman J, et al. A randomized, controlled trial of recombinant alpha-interferon therapy for chronic hepatitis B. Am J Gastroenterol. 1993;88(11):1887-92. [pmid: 8237937].
Dienstag JL, Stevens CE, Bhan AK, Szmuness W. Hepatitis B Vaccine administered to chronic carriers of hepatitis b surface antigen. Ann Intern Med. 1982;96(5):575-9. [pmid: 7073149].
Dusheiko GM, Paterson AC, Pitcher L, Kassianides C, DiBisceglie AM, Song E, et al. Recombinant leucocyte interferon treatment of chronic hepatitis B. An analysis of two therapeutic trials. J Hepatol. Suppl 2. 1986;3:S199-207. [pmid: 3298408].
Economou M, Manolakopoulos S, Trikalinos TA, Filis S, Bethanis S, Tzourmakliotis D, et al. Interferon-alpha plus lamivudine vs lamivudine reduces breakthroughs, but does not affect sustained response in HBeAg negative chronic hepatitis B. World J Gastroenterol. 2005;11(37):5882-7. [pmid: 16270403].
Eyigun CP, Yilmaz S, Gul C, Sengul A, Hacibektasoglu A, Van Thiel DH. A comparative trial of two surface subunit recombinant hepatitis B Vaccines vs a surface and PreS subunit Vaccine for immunization of healthy adults. J Viral Hepat. 1998;5(4):265-9. [pmid: 9751013].
Fan XH, Geng JZ, Wang LF, Zheng YY, Lu HY, Li J, et al. De novo combination therapy with lamivudine and adefovir dipivoxil in chronic hepatitis B patients. World J Gastroenterol. 2011;17(43):4804-9. [pmid: 22147982].
Fattovich G, Brollo L, Boscaro S, Pontisso P, Giustina G, Criscuolo D, et al. Long-term effect of low dose recombinant interferon therapy in patients with chronic hepatitis B. J Hepatol. 1989;9(3):331-7. [pmid: 2691568].
Fattovich G, Brollo L, Pontisso P, Pornaro E, Rugge M, Alberti A, et al. Levamisole therapy in chronic type B hepatitis. Results of a double-blind randomized trial. Gastroenterology. 1986;91(3):692-6. [pmid: 3525317].
Fattovich G, Farci P, Rugge M, Brollo L, Mandas A, Pontisso P, et al. A randomized controlled trial of lymphoblastoid interferon-alpha in patients with chronic hepatitis B lacking HBeAg. Hepatology. 1992;15(4):584-9. [pmid: 1551634].
Fattovich G, Giustina G, Alberti A, Guido M, Pontisso P, Favarato S, et al. A randomized controlled trial of thymopentin therapy in patients with chronic hepatitis B. J Hepatol. 1994;21(3):361-6. [pmid: 7836705].
Fattovich G, Giustina G, Brollo L, Guido M, Pontisso P, Noventa F, et al. Therapy for chronic hepatitis B with lymphoblastoid interferon-alpha and levamisole. Hepatology. 1992;16(5):1115-9. [pmid: 1427652].
Fevery J, Elewaut A, Michielsen P, Nevens F, Van Eyken P, Adler M, et al. Efficacy of interferon alfa-2b with or without prednisone withdrawal in the treatment of chronic viral hepatitis B. A prospective double-blind Belgian-Dutch study. J Hepatol. 1990;11(1).
Flink HJ, Sprengers D, Hansen BE, van Zonneveld M, de Man RA, Schalm SW, et al. Flares in chronic hepatitis B patients induced by the host or the virus? Relation to treatment response during Peg-interferon {alpha}-2b therapy. Gut. 2005;54(11):1604-9. [pmid: 15923670].
Flink HJ, van Zonneveld M, Hansen BE, de Man RA, Schalm SW, Janssen HL. Treatment with Peg-interferon alpha-2b for HBeAg-positive chronic hepatitis B: HBsAg loss is associated with HBV genotype. Am J Gastroenterol. 2006;101(2):297-303. [pmid: 16454834].
Flisiak R, Prokopowicz D. Effect of misoprostol on the course of viral hepatitis B. HepatoGastroenterology. 1997;44(17):1419-25. [pmid: 9356866].
Garcia G, Smith CI, Weissberg JI, Eisenberg M, Bissett J, Nair PV, et al. Adenine arabinoside monophosphate (vidarabine phosphate) in combination with human leukocyte interferon in the treatment of chronic hepatitis B. A randomized, double-blinded, placebo-controlled trial. Ann Intern Med. 1987;107(3):278-85. [pmid: 2441633].
Hoofnagle JH, Davis GL, Pappas SC, Hanson RG, Peters M, Avigan MI, et al. A short course of prednisolone in chronic type B hepatitis. Report of a randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1986;104(1):12-7. [pmid: 3940480].
Hoofnagle JH, Hanson RG, Minuk GY, Pappas SC, Schafer DF, Dusheiko GM, et al. Randomized controlled trial of adenine arabinoside monophosphate for chronic type B hepatitis. Gastroenterology. 1984;86(1):150-7. [pmid: 6196251].
Hoofnagle JH, Peters M, Mullen KD, Jones DB, Rustgi V, Di Bisceglie A, et al. Randomized, controlled trial of recombinant human alpha-interferon in patients with chronic hepatitis B. Gastroenterology. 1988;95(5):1318-25. [pmid: 3049216].
Itoh S, Marutani K, Matsuo S. Changes in ultrastructure of hepatocytes and liver test results before, during, and after treatment with interferon-beta in patients with HB(e)Ag-positive chronic active hepatitis. Dig Dis Sci. 1992;37(8):1260-7. [pmid: 1499452].
Jain S, Thomas HC, Oxford JS, Sherlock S. Trial of ribavirin for the treatment of HBsAg positive chronic liver disease. J Antimicrob Chemother. 1978;4(4):367-73. [pmid: 690037].
Janssen HL, Berk L, Heijtink RA, ten Kate FJ, Schalm SW. Interferon-alpha and zidovudine combination therapy for chronic hepatitis B: results of a randomized, placebo-controlled trial. Hepatology. 1993;17(3):383-8. [pmid: 8444411].
Janssen HL, van Zonneveld M, Senturk H, Zeuzem S, Akarca US, Cakaloglu Y, et al. Pegylated interferon alfa-2b alone or in combination with lamivudine for HBeAg-positive chronic hepatitis B: a randomised trial. Lancet. 2005;365(9454):123-9. [pmid: 15639293].
Kaygusuz I, Ozturk Kaygusuz T, Ozturk A, Kilic SS, Karlidag T, Keles E, et al. Effects of interferon-alpha2b on hearing. Int J Audiol. 2004;43(8):438-41. [pmid: 15643736].
Kim YJ, Cho HC, Sinn DH, Gwak GY, Choi MS, Koh KC, et al. Frequency and risk factors of renal impairment during long-term adefovir dipivoxil treatment in chronic hepatitis B patients. J Gastroenterol Hepatol. 2012;27(2):306-12. [pmid: 21777281].
Kleiner DE, Gaffey MJ, Sallie R, Tsokos M, Nichols L, McKenzie R, et al. Histopathologic changes associated with fialuridine hepatotoxicity. Mod Pathol. 1997;10(3):192-9. [pmid: 9071726].
Krogsgaard K. The long-term effect of treatment with interferon-alpha 2a in chronic hepatitis B. The Long-Term Follow-up Investigator Group. The European Study Group on Viral Hepatitis (EUROHEP). Executive Team on Anti-Viral Treatment. J Viral Hepat. 1998;5(6):389-97. [pmid: 9857348].
Lai CL, Leung N, Teo EK, Tong M, Wong F, Hann HW, et al. A 1-year trial of telbivudine, lamivudine, and the combination in patients with hepatitis B e antigen-positive chronic hepatitis B. Gastroenterology. 2005;129(2):528-36. [pmid: 16083710].
Lam ET, Lam CL, Lai CL, Yuen MF, Fong DY, So TM. Health-related quality of life of Southern Chinese with chronic hepatitis B infection. Health Qual Life Outcomes. 2009;7:52. [pmid: 19500349].
Lau JY, Lai CL, Wu PC, Chung HT, Lok AS, Lin HJ. A randomised controlled trial of recombinant interferon-gamma in Chinese patients with chronic hepatitis B virus infection. J Med Virol. 1991;34(3):184-7. [pmid: 1919540].
Lee HS, Chung YH, Lee K, Byun KS, Paik SW, Han JY, et al. A 12-week clevudine therapy showed potent and durable antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. 2006;43(5):982-8. [pmid: 16628625].
Lee SD, Tong MJ, Wu JC, Lin HC, Tsai YT, Lo KJ. A randomised double-blind placebo-controlled trial of prednisolone therapy in HBeAg and HBV DNA positive Chinese patients with chronic active hepatitis B. J Hepatol. 1991;12(2):246-50. [pmid: 2051004].
Lee SU, Choi KH, Ha BJ, Suh SY, Han BH, Ku JY, et al. Effect of adenine arabinoside and alpha-interferon in patients with HBeAg-positive chronic active hepatitis. Korean J Intern Med. 1990;5(1):1-4. [pmid: 2271507].
Liaw YF, Lin SM, Chen TJ, Chien RN, Sheen IS, Chu CM. Beneficial effect of prednisolone withdrawal followed by human lymphoblastoid interferon on the treatment of chronic type B hepatitis in Asians: a randomized controlled trial. J Hepatol. 1994;20(2):175-80. [pmid: 8006397].
Liaw YF, Raptopoulou-Gigi M, Cheinquer H, Sarin SK, Tanwandee T, Leung N, et al. Efficacy and safety of entecavir versus adefovir in chronic hepatitis B patients with hepatic decompensation: a randomized, open-label study. Hepatology. 2011;54(1):91-100. [pmid: 21503940].
Lim SG, Krastev Z, Ng TM, Mechkov G, Kotzev IA, Chan S, et al. Randomized, double-blind study of emtricitabine (FTC) plus clevudine versus FTC alone in treatment of chronic hepatitis B. Antimicrob Agents Chemother. 2006;50(5):1642-8. [pmid: 16641430].
Lim SG, Ng TM, Kung N, Krastev Z, Volfova M, Husa P, et al. A double-blind placebo-controlled study of emtricitabine in chronic hepatitis B. Arch Intern Med. 2006;166(1):49-56. [pmid: 16401810].
Lin SM, Tai DI, Chien RN, Sheen IS, Chu CM, Liaw YF. Comparison of long-term effects of lymphoblastoid interferon alpha and recombinant interferon alpha-2a therapy in patients with chronic hepatitis B. J Viral Hepat. 2004;11(4):349-57. [pmid: 15230858].
Liu JP, McIntosh H, Lin H. Chinese medicinal herbs for asymptomatic carriers of hepatitis B virus infection. Cochrane Database Syst Rev. 2009;(1).
Liu JP, Wang J. Acupuncture for chronic hepatitis B virus infection. Cochrane Database Syst Rev. 2009;(1).
Lok AS, Lai CL, Wu PC. Interferon therapy of chronic hepatitis B virus infection in Chinese. J Hepatol. 1986;3(2):S209-15. [pmid: 3036936].
Lok AS, Lai CL, Wu PC, Leung EK. Long-term follow-up in a randomised controlled trial of recombinant alpha 2-interferon in Chinese patients with chronic hepatitis B infection. Lancet. 1988;2(8606):298-302. [pmid: 2899719].
Lok AS, Wilson LA, Thomas HC. Neurotoxicity associated with adenine arabinoside monophosphate in the treatment of chronic hepatitis B virus infection. J Antimicrob Chemother. 1984;14(1):93-9. [pmid: 6207158].
Ly KN, Xing J, Klevens RM, Jiles RB, Ward JW, Holmberg SD. The increasing burden of mortality from viral hepatitis in the United States between 1999 and 2007. Ann Intern Med. 2012;156(4):271-8. [pmid: 22351712].
Main J, Brown JL, Howells C, Galassini R, Crossey M, Karayiannis P, et al. A double blind, placebo-controlled study to assess the effect of famciclovir on virus replication in patients with chronic hepatitis B virus infection. J Viral Hepat. 1996;3(4):211-5. [pmid: 8871884].
Manolakopoulos S, Striki A, Deutsch M, Mela M, Ketikoglou I, Tzourmakliotis D, et al. Long-term adefovir plus lamivudine therapy does not decrease creatinine clearance in HBeAg-negative chronic hepatitis B patients. Liver Int. 2011;31(10):1525-32. [pmid: 22093327].
Manzillo G, Piccinino F, Sagnelli E, Izzo CM, Pasquale G, Maio G, et al. Treatment of HBsAg-positive chronic active hepatitis with corticosteroids and/or azathioprine. A prospective study. Ric Clin Lab. 1983;13(2):261-8. [pmid: 6622929].
Marcellin P, Lau GKK, Zeuzem S, Heathcote EJ, Pockros PJ, Reddy KR, et al. Comparing the safety, tolerability and quality of life in patients with chronic hepatitis B vs chronic hepatitis C treated with peginterferon alpha-2a. Liver Int. 2008;28(4):477-85. [pmid: 18339074].
Marcellin P, Mommeja-Marin H, Sacks SL, Lau GKK, Sereni D, Bronowicki JP, et al. A phase II dose-escalating trial of clevudine in patients with chronic hepatitis B. Hepatology. 2004;40(1):140-8. [pmid: 15239097].
Marcellin P, Ouzan D, Degos F, Brechot C, Metman EH, Degott C, et al. Randomized controlled trial of adenine arabinoside 5'-monophosphate in chronic active hepatitis B: comparison of the efficacy in heterosexual and homosexual patients. Hepatology. 1989;10(3):328-31. [pmid: 2474480].
Marcellin P, Pouteau M, Loriot MA, Boyer N, Degos F, Cales P, et al. Adenine arabinoside 5'-monophosphate in patients with chronic hepatitis B: comparison of the efficacy in patients with high and low viral replication. Gut. 1995;36(3):422-6. [pmid: 7535285].
Martin J, Bosch O, Moraleda G, Bartolome J, Quiroga JA, Carreno V. Pilot study of recombinant human granulocyte-macrophage colony-stimulating factor in the treatment of chronic hepatitis B. Hepatology. 1993;18(4):775-80. [pmid: 8406350].
Martin P, Hann HW, Westerberg S, Munoz SJ, Rubin R, Maddrey WC. Interferon-alpha2b therapy is efficacious in Asian-Americans with chronic hepatitis B infection: a prospective controlled trial. Dig Dis Sci. 1998;43(4):875-9. [pmid: 9580255].
Mazzella G, Saracco G, Rizetto M, Amed MA, Gonzalez Quintela A, Rosina F, et al. Human lymphoblastoid interferon for the treatment of chronic hepatitis B. A randomized controlled trial. Am J Med. 1988;85(2A):141-2. [pmid: 3044077].
Mazzella G, Villanova N, Abdu-Ahmed M, Barbara L, Saracco G, Rizzetto M, et al. Treatment of chronic hepatitis B with human lymphoblastoid interferon: results of a controlled trial. Chemioterapia. 1988;7(3):12-4. [pmid: 3073868].
Mellerup MT, Krogsgaard K, Gluud C. Glucocorticosteroids for viral hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Mellerup MT, Krogsgaard K, Mathurin P, Gluud C, Poynard T. Sequential combination of glucocorticosteroids and alfa interferon versus alfa interferon alone for HBeAg-positive chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Mendez-Navarro J, Corey KE, Zheng H, Barlow LL, Jang JY, Lin W, et al. Hepatitis B screening, prophylaxis and re-activation in the era of rituximab-based chemotherapy. Liver Int. 2011;31(3):330-9. [pmid: 20738779].
Merchant RC, Keshavarz R. Patterns in the offering of hepatitis B prophylaxis by US emergency department physicians. Infect Control Hosp Epidemiol. 2006;27(7):764-6. [pmid: 16807856].
Mihm U, Gartner BC, Faust D, Hofmann WP, Sarrazin C, Zeuzem S, et al. Viral kinetics in patients with lamivudine-resistant hepatitis B during adefovir-lamivudine combination therapy. J Hepatol. 2005;43(2):217-24. [pmid: 15964093].
Milazzo F, Galli M, Fassio PG, Cargnel A, Pugliese A, Tovo PA, et al. Attempted treatment of fulminant viral hepatitis with human fibroblast interferon. Infection. 1985;13(3):130-3. [pmid: 3897068].
Milne A, Hopkirk N, Lucas CR, Waldon J, Foo Y. Failure of New Zealand hepatitis B carriers to respond to Phyllanthus amarus. N Z Med J. 1994;107(980):243. [pmid: 8208497].
Mitsui F, Tsuge M, Kimura T, Kitamura S, Abe H, Saneto H, et al. Importance of serum concentration of adefovir for Lamivudine-adefovir combination therapy in patients with lamivudine-resistant chronic hepatitis B. Antimicrob Agents Chemother. 2010;54(8):3205-11. [pmid: 20498322].
Morrison DS, Gilchrist G. Prison admission health screening as a measure of health needs. Health Bull (Edinb). 2001;59(2):114-9. [pmid: 12664725].
Moschos M, Manesis E, Panagakis E, Brouzas D, Hadziyannis S, Theodossiadis G. The effect of low-dose interferon treatment on visual evoked potentials. Doc Ophthalmol. 1997;94(3):215-21. [pmid: 9682991].
Moucari R, Boyer N, Ripault MP, Castelnau C, Mackiewicz V, Dauvergne A, et al. Sequential therapy with adefovir dipivoxil and pegylated interferon alfa-2a for HBeAg-negative patients. J Viral Hepat. 2011;18(8):580-6. [pmid: 20487260].
Muller R, Klein H, Vido I, Niehoff G, Lautz HU, Gebel M, et al. Antiviral treatment in chronic hepatitis B. Data of 5 prospectively controlled randomized trials. J Hepatol. Suppl 2. 1986;3:S217-23. [pmid: 2439573].
Mutchnick MG, Appelman HD, Chung HT, Aragona E, Gupta TP, Cummings GD, et al. Thymosin treatment of chronic hepatitis B: a placebo-controlled pilot trial. Hepatology. 1991;14(3):409-15. [pmid: 1874487].
Mutimer D, Naoumov N, Honkoop P, Marinos G, Ahmed M, de Man R, et al. Combination alpha-interferon and lamivudine therapy for alpha-interferon-resistant chronic hepatitis B infection: results of a pilot study. J Hepatol. 1998;28(6):923-9. [pmid: 9672165].
Nair PV, Tong MJ, Kempf R, Co R, Lee SD, Venturi CL. Clinical, serologic, and immunologic effects of human leukocyte interferon in HBsAg-positive primary hepatocellular carcinoma. Cancer. 1985;56(5):1018-22. [pmid: 2990662].
Niederau C, Heintges T, Niederau M, Stremmel W, Strohmeyer G. Prospective randomized controlled trial of sequential treatment with corticoids and alpha-interferon versus treatment with interferon alone in patients with chronic active hepatitis B. Eur J Med. 1992;1(7):396-402. [pmid: 1341478].
Niro GA, Fontana R, Gioffreda D, Fiorella S, Accadia L, Iacobellis A, et al. Sequential treatment with lamivudine and alpha-interferon in anti-HBe-positive chronic hepatitis B patients: a pilot study. Dig Liver Dis. 2007;39(9):857-63. [pmid: 17652045].
Papadopoulos VP, Chrysagis DN, Protopapas AN, Goulis IG, Dimitriadis GT, Mimidis KP. Peginterferon alfa-2b as monotherapy or in combination with lamivudine in patients with HBeAg-negative chronic hepatitis B: a randomised study. Med Sci Monit. 2009;15(2):CR56-61. [pmid: 19179968].
Pastore G, Santantonio T, Milella M, Monno L, Mariano N, Moschetta R, et al. Anti-HBe-positive chronic hepatitis B with HBV-DNA in the serum response to a 6-month course of lymphoblastoid interferon. J Hepatol. 1992;14(2-3):221-5. [pmid: 1500686].
Pastore G, Santantonio T, Monno L, Milella M, Luchena N, Angarano G. Permanent inhibition of viral replication induced by low dosage of human leukocyte interferon in patients with chronic hepatitis B. HepatoGastroenterology. 1988;35(2):57-61. [pmid: 3371847].
Perez V, Findor J, Tanno H, Sorda J. A controlled trial of high dose interferon, alone and after prednisone withdrawal, in the treatment of chronic hepatitis B: long term follow up. Gut. 1993;34(2 Suppl):S91-4. [pmid: 8314497].
Perrillo R, Hann HW, Mutimer D, Willems B, Leung N, Lee WM, et al. Adefovir dipivoxil added to ongoing lamivudine in chronic hepatitis B with YMDD mutant hepatitis B virus. Gastroenterology. 2004;126(1):81-90. [pmid: 14699490].
Perrillo RP. The use of corticosteroids in conjunction with antiviral therapy in chronic hepatitis B with ongoing viral replication. J Hepatol. Suppl 2. 1986;3:S57-64. [pmid: 2439577].
Perrillo RP, Regenstein FG, Bodicky CJ, Campbell CR, Sanders GE, Sunwoo YC. Comparative efficacy of adenine arabinoside 5' monophosphate and prednisone withdrawal followed by adenine arabinoside 5' monophosphate in the treatment of chronic active hepatitis type B. Gastroenterology. 1985;88(3):780-6. [pmid: 2578421].
Perrillo RP, Regenstein FG, Peters MG, DeSchryver-Kecskemeti K, Bodicky CJ, Campbell CR, et al. Prednisone withdrawal followed by recombinant alpha interferon in the treatment of chronic type B hepatitis. A randomized, controlled trial. Ann Intern Med. 1988;109(2):95-100. [pmid: 3289433].
Peters MG, Hann Hw H, Martin P, Heathcote EJ, Buggisch P, Rubin R, et al. Adefovir dipivoxil alone or in combination with lamivudine in patients with lamivudine-resistant chronic hepatitis B. Gastroenterology. 2004;126(1):91-101. [pmid: 14699491].
Petersen J, Ratziu V, Buti M, Janssen HLA, Brown A, Lampertico P, et al. Entecavir plus tenofovir combination as rescue therapy in pre-treated chronic hepatitis B patients: an international multicenter cohort study. J Hepatol. 2012;56(3):520-6. [pmid: 22037226].
Piccolo P, Lenci I, Demelia L, Bandiera F, Piras MR, Antonucci G, et al. A randomized controlled trial of pegylated interferon-alpha2a plus adefovir dipivoxil for hepatitis B e antigen-negative chronic hepatitis B. Antivir Ther. 2009;14(8):1165-74. [pmid: 20032546].
Pol S, Couillin I, Michel ML, Driss F, Nalpas B, Carnot F, et al. Immunotherapy of chronic hepatitis B by anti HBV Vaccine. Acta Gastroenterol Belg. 1998;61(2):228-33. [pmid: 9658616].
Pol S, Nalpas B, Driss F, Michel ML, Tiollais P, Denis J, et al. Efficacy and limitations of a specific immunotherapy in chronic hepatitis B. J Hepatol. 2001;34(6):917-21. [pmid: 11451177].
Porres JC, Carreno V, Mora I, Gutiez J, Moreno A, Ramon y Cajal S, et al. Different doses of recombinant alpha interferon in the treatment of chronic hepatitis B patients without antibodies against the human immunodeficiency virus. HepatoGastroenterology. 1988;35(6):300-3. [pmid: 3215626].
Qian MYY, Yuwei JR, Angus P, Schelleman T, Johnson L, Gow P. Efficacy and cost of a hepatocellular carcinoma screening program at an Australian teaching hospital. J Gastroenterol Hepatol. 2010;25(5):951-6. [pmid: 20546449].
Realdi G, Fattovich G, Pastore G, Caredda F, Noventa F, Santantonio T, et al. Problems in the management of chronic hepatitis B with interferon: experience in a randomized, multicentre study. J Hepatol. Suppl 1. 1990;11:S129-32. [pmid: 2079570].
Reichen J, Bianchi L, Frei PC, Male PJ, Lavanchy D, Schmid M. Efficacy of steroid withdrawal and low-dose interferon treatment in chronic active hepatitis B. Results of a randomized multicenter trial. Swiss Association for the Study of the Liver. J Hepatol. 1994;20(2):168-74. [pmid: 8006396].
Ren FY, Jin H, Piao XX, Piao FS. Ribavirin and IFN-alpha combination therapy induces CD4+ T-cell proliferation and Th1 cytokine secretion in patients with chronic hepatitis B. World J Gastroenterol. 2007;13(41):5440-5. [pmid: 17907286].
Robson SC, Brice E, van Rensburg C, Kannemeyer J, Hift RJ, Kirsch RE. Safety and efficacy of interferon alpha-2b following prednisone withdrawal in the treatment of chronic viral hepatitis B. A case-controlled, randomised study. S Afr Med J. 1992;82(5):317-20. [pmid: 1448711].
Rodriguez-Inigo E, Bartolome J, Lopez-Alcorocho JM, Contonat T, Oliva H, Carreno V. Activation of liver disease in healthy hepatitis B surface antigen carriers during interferon-alpha treatment. J Med Virol. 1997;53(1):76-80. [pmid: 9298736].
Romeo F, Palmisano L, Arcoria D. Thymostimulin in the treatment of hepatitis B surface antigen-positive chronic active hepatitis. Controlled clinical trial--two years follow-up. Arzneimittelforschung. 1987;37(4):450-6. [pmid: 3300664].
Rumi M, Romeo R, De Filippi F, Marcelli R, Del Ninno E, van Eyken P, et al. A multicentre randomized clinical trial of recombinant alpha-2a interferon therapy in patients with chronic hepatitis B. Ital J Gastroenterol. 1993;25(3):117-20. [pmid: 8507888].
Ryu HJ, Lee JM, Ahn SH, Kim DY, Lee MH, Han KH, et al. Efficacy of adefovir add-on lamivudine rescue therapy compared with switching to entecavir monotherapy in patients with lamivudine-resistant chronic hepatitis B. J Med Virol. 2010;82(11):1835-42. [pmid: 20872709].
Saconato H, Atallah AN, Souza GM, Parise ER. Thymosin alpha1 for chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Saconato H, Souza GM, Atallah AN, Parise ER. Foscarnet for chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Sagnelli E, Piccinino F, Manzillo G, Felaco FM, Filippini P, Maio G, et al. Effect of immunosuppressive therapy on HBsAg-positive chronic active hepatitis in relation to presence or absence of HBeAg and anti-HBe. Hepatology. 1983;3(5):690-5. [pmid: 6618436].
Sangfelt P, Uhnoo I, Hollander A, Lindh G, Weiland O. Lamivudine and famciclovir combination therapy with or without addition of interferon-alpha-2b for HBeAg-positive chronic hepatitis B: a pilot study. Scand J Infect Dis. 2002;34(7):505-11. [pmid: 12195876].
Santantonio T, Niro GA, Sinisi E, Leandro G, Insalata M, Guastadisegni A, et al. Lamivudine/interferon combination therapy in anti-HBe positive chronic hepatitis B patients: a controlled pilot study. J Hepatol. 2002;36(6):799-804. [pmid: 12044531].
Saracco G, Mazzella G, Rosina F, Cancellieri C, Lattore V, Raise E, et al. A controlled trial of human lymphoblastoid interferon in chronic hepatitis B in Italy. Hepatology. 1989;10(3):336-41. [pmid: 2668148].
Sarin SK, Kumar M, Kumar R, Kazim SN, Guptan RC, Sakhuja P, et al. Higher efficacy of sequential therapy with interferon-alpha and lamivudine combination compared to lamivudine monotherapy in HBeAg positive chronic hepatitis B patients. Am J Gastroenterol. 2005;100(11):2463-71. [pmid: 16279901].
Saruc M, Ozden N, Turkel N, Ayhan S, Hock LM, Tuzcuoglu I, et al. Long-term outcomes of thymosin-alpha 1 and interferon alpha-2b combination therapy in patients with hepatitis B e antigen (HBeAg) negative chronic hepatitis B. J Pharm Sci. 2003;92(7):1386-95. [pmid: 12820143].
Schalm SW. Treatment of chronic hepatitis B with a combination of acyclovir and human lymphoblastoid interferon. Chemioterapia. 1988;7(3):26-9. [pmid: 3248317].
Schalm SW, Heathcote J, Cianciara J, Farrell G, Sherman M, Willems B, et al. Lamivudine and alpha interferon combination treatment of patients with chronic hepatitis B infection: a randomised trial. Gut. 2000;46(4):562-8. [pmid: 10716688].
Schalm SW, Heijtink RA. Spontaneous disappearance of viral replication and liver cell inflammation in HBsAg-positive chronic active hepatitis: results of a placebo vs. interferon trial. Hepatology. 1982;2(6):791-4. [pmid: 7141389].
Schalm SW, Heytink RA, van Buuren HR, de Man RA. Acyclovir enhances the antiviral effect of interferon in chronic hepatitis B. Lancet. 1985;2(8451):358-60. [pmid: 2862516].
Schattner A, Revel M. Interferon treatment for hepatitis. Isr J Med Sci. 1989;25(7):357-9. [pmid: 2474520].
Scotto G, Palumbo E, Fazio V, Cibelli DC, Saracino A, Angarano G. Efficacy and tolerability of lamivudine alone versus lamivudine plus alpha-interferon for treatment of chronic active hepatitis B in patients with a precore-mutant variant. Infez Med. 2006;14(3):145-51. [pmid: 17127828].
Scully LJ, Shein R, Karayiannis P, McDonald JA, Thomas HC. Lymphoblastoid interferon therapy of chronic HBV infection. A comparison of 12 vs. 24 weeks of thrice weekly treatment. J Hepatol. 1987;5(1):51-8. [pmid: 3655310].
Senturk H, Tabak F, Ozaras R, Erdem L, Canbakan B, Mert A, et al. Efficacy of pre-S-containing HBV Vaccine combined with lamivudine in the treatment of chronic HBV infection. Dig Dis Sci. 2009;54(9):2026-30. [pmid: 19016327].
Shi M, Wang RS, Zhang H, Zhu YF, Han B, Zhang Y, et al. Sequential treatment with lamivudine and interferon-alpha monotherapies in hepatitis B e antigen-negative Chinese patients and its suppression of lamivudine-resistant mutations. J Antimicrob Chemother. 2006;58(5):1031-5. [pmid: 16987866].
Sjogren MH, Hoofnagle JH, Waggoner JG. Effect of corticosteroid therapy on levels of antibody to hepatitis B core antigen in patients with chronic type B hepatitis. Hepatology. 1987;7(3):582-5. [pmid: 3552925].
Smith CI, Kitchen LW, Scullard GH, Robinson WS, Gregory PB, Merigan TC. Vidarabine monophosphate and human leukocyte interferon in chronic hepatitis B infection. JAMA. 1982;247(16):2261-5. [pmid: 6175774].
Soloway RD, Summerskill WH, Baggenstoss AH, Geall MG, Gitnick GL, Elveback IR, et al. Clinical, biochemical, and histological remission of severe chronic active liver disease: a controlled study of treatments and early prognosis. Gastroenterology. 1972;63(5):820-33. [pmid: 4538724].
Song JW, Zhang G, Lin JG, Tang WX, Lin JS. Clinical study of lamivudine and interferon combinate administration to inhibit hepatitis B virus replication. Zhonghua Gan Zang Bing Za Zhi. 2004;12(10):593-6. [pmid: 15504288].
Sun X, Qin W, Zhou R, Wang L, Li Y, Zhao L. Effect of conventional interferon- in patients with HBeAg-positive chronic hepatitis B: a systematic review and meta-analysis. J Evid Based Med. 2010;3(4):220-5. [pmid: 21349073].
Suzuki H, Yamamoto S, Hirayama C, Takino T, Fujisawa K, Oda T. Cianidanol therapy for HBe-antigen-positive chronic hepatitis: a multicentre, double-blind study. Liver. 1986;6(1):35-44. [pmid: 3520204].
Takkenberg B, Terpstra V, Zaaijer H, Weegink C, Dijkgraaf M, Jansen P, et al. Intrahepatic response markers in chronic hepatitis B patients treated with peginterferon alpha-2a and adefovir. J Gastroenterol Hepatol. 2011;26(10):1527-35. [pmid: 21557773].
Tanaka H, Shiota G, Kawasaki H. Interferon-alpha therapy alters glucose metabolism in patients with chronic hepatitis B. J Med. 1997;28(5-6):325-34. [pmid: 9604791].
Tangkijvanich P, Thong-ngam D, Mahachai V, Kladchareon N, Suwangool P, Kullavanijaya P. Long-term effect of interferon therapy on incidence of cirrhosis and hepatocellular carcinoma in Thai patients with chronic hepatitis B. Southeast Asian J Trop Med Public Health. 2001;32(3):452-8. [pmid: 11944697].
Tassopoulos NC, Koutelou MG, Polychronaki H, Paraloglou-Ioannides M, Hadziyannis SJ. Recombinant interferon-alpha therapy for acute hepatitis B: a randomized, double-blind, placebo-controlled trial. J Viral Hepat. 1997;4(6):387-94. [pmid: 9430359].
Teran JC, Mullen KD, Hoofnagle JH, McCullough AJ. Decrease in serum levels of markers of hepatic connective tissue turnover during and after treatment of chronic hepatitis B with interferon-alpha. Hepatology. 1994;19(4):849-56. [pmid: 8138256].
Teuber G, Dienes HP, Meyer Zum Buschenfelde KH, Gerken G. Long-term follow-up of patients with chronic hepatitis B after interferon treatment. Z Gastroenterol. 1996;34(4):230-6. [pmid: 8686350].
Thomas HC, Lok AS, Carreno V, Farrell G, Tanno H, Perez V, et al. Comparative study of three doses of interferon-alpha 2a in chronic active hepatitis B. The International Hepatitis Trial Group. J Viral Hepat. 1994;1(2):139-48. [pmid: 8790569].
Tine F, Liberati A, Craxi A, Almasio P, Pagliaro L. Interferon treatment in patients with chronic hepatitis B: a meta-analysis of the published literature. J Hepatol. 1993;18(2):154-62. [pmid: 7691924].
Trepo C, Rougier P, Bizollon T, Poupon R, Zarski JP, Quinton A, et al. Combination therapy with ARA-AMP and interferon of chronic active hepatitis B. Interim analysis of an ongoing study. J Hepatol. 1991;13(1):S3. [pmid: 1720439].
Truong BX, Seo Y, Kato M, Hamano K, Ninomiya T, Katayama M, et al. Long-term follow-up of Japanese patients with chronic hepatitis B treated with interferon-alpha. Int J Mol Med. 2005;16(2):279-84. [pmid: 16012762].
van Zonneveld M, Flink HJ, Verhey E, Senturk H, Zeuzem S, Akarca US, et al. The safety of pegylated interferon alpha-2b in the treatment of chronic hepatitis B: predictive factors for dose reduction and treatment discontinuation. Aliment Pharmacol Ther. 2005;21(9):1163-71. [pmid: 15854180].
van Zonneveld M, Zondervan PE, Cakaloglu Y, Simon C, Akarca US, So TM, et al. Peg-interferon improves liver histology in patients with HBeAg-positive chronic hepatitis B: no additional benefit of combination with lamivudine. Liver Int. 2006;26(4):399-405. [pmid: 16629642].
Vandepapeliere P, Lau GKK, Leroux-Roels G, Horsmans Y, Gane E, Tawandee T, et al. Therapeutic vaccination of chronic hepatitis B patients with virus suppression by antiviral therapy: a randomized, controlled study of co-administration of HBsAg/AS02 candidate Vaccine and lamivudine. Vaccine. 2007;25(51):8585-97. [pmid: 18031872].
Waked I, Amin M, Abd-el Fattah SA, Osman L, Sabbour M. Interferon in chronic active hepatitis B. Preliminary results. Chemioterapia. 1988;7(3):198-202. [pmid: 3168077].
Wang XY, Zhang XX, Yao X, Jiang JH, Xie YH, Yuan ZH, et al. Serum HBeAg sero-conversion correlated with decrease of HBsAg and HBV DNA in chronic hepatitis B patients treated with a therapeutic Vaccine. Vaccine. 2010;28(51):8169-74. [pmid: 20937312].
Weimar W, Heijtink RA, ten Kate FJ, Schalm SW, Masurel N, Schellekens H, et al. Double-blind study of leucocyte interferon administration in chronic HBsAg-positive hepatitis. Lancet. 1980;1(8164):336-8. [pmid: 6101791].
Weller IV. A randomised controlled trial of adenine arabinoside 5'-monophosphate (ARA-AMP) in chronic hepatitis B virus infection. J Hepatol. Suppl 2. 1986;3:S107-10. [pmid: 2439568].
Weller IV, Carreno V, Fowler MJ, Monjardino J, Makinen D, Varghese Z, et al. Acyclovir in hepatitis B antigen-positive chronic liver disease: inhibition of viral replication and transient renal impairment with iv bolus administration. J Antimicrob Chemother. 1983;11(3):223-31. [pmid: 6841304].
Weller IV, Lok AS, Mindel A, Karayiannis P, Galpin S, Monjardino J, et al. Randomised controlled trial of adenine arabinoside 5'-monophosphate (ARA-AMP) in chronic hepatitis B virus infection. Gut. 1985;26(7):745-51. [pmid: 2410328].
Whitfield K, Stoey SL, Skoog M, Lindschou Hansen J, Mumtaz K, Gluud C. Levamisole for chronic hepatitis B. Cochrane Database Syst Rev. 2010;(11).
Williams SJ, Craig PI, Cooksley WG, Bye WA, Bilous M, Grierson JM, et al. Randomised controlled trial of recombinant human interferon -alpha A for chronic active hepatitis B. Aust N Z J Med. 1990;20(1):9-19. [pmid: 2181991].
Wong DK, Cheung AM, O'Rourke K, Naylor CD, Detsky AS, Heathcote J. Effect of alpha-interferon treatment in patients with hepatitis B e antigen-positive chronic hepatitis B. A meta-analysis. Ann Intern Med. 1993;119(4):312-23. [pmid: 8328741].
Wu T, Roger H, Xie L, Liu G, Hao B. Bicyclol for chronic hepatitis B. Cochrane Database Syst Rev. 2006;(4):CD004480. [pmid: 17054206].
Wu T, Xie L, Liu GJ, Hao B, Harrison RA. Bicyclol for chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Xia Y, Han M, Liu PJ, Gluud C. Glycyrrhizin for chronic hepatitis B virus infection. Cochrane Database Syst Rev. 2011;(1).
Xia Y, Liu PJ, Gluud C. Glycyrrhizin versus antiviral drugs for chronic hepatitis B virus infection. Cochrane Database Syst Rev. 2011;(2).
Yalcin K, Danis R, Degertekin H, Alp MN, Tekes S, Budak T. The lack of effect of therapeutic vaccination with a pre-S2/S HBV Vaccine in the immune tolerant phase of chronic HBV infection. J Clin Gastroenterol. 2003;37(4):330-5. [pmid: 14506391].
Yalcin K, Degertekin H, Yildiz F, Celik Y. Comparison of 12-month courses of interferon-alpha-2b-lamivudine combination therapy and interferon-alpha-2b monotherapy among patients with untreated chronic hepatitis B. Clin Infect Dis. 2003;36(12):1516-22. [pmid: 12802750].
Yang HJ, Lee JH, Kim YJ, Yoon JH, Lee HS. Antiviral efficacy of combination therapy with entecavir and adefovir for entecavir/lamivudine-resistant hepatitis B virus with or without adefovir resistance. J Med Virol. 2012;84(3):424-30. [pmid: 22246827].
Yang YF, Zhao W, Zhong YD, Yang YJ, Shen L, Zhang N, et al. Comparison of the efficacy of thymosin alpha-1 and interferon alpha in the treatment of chronic hepatitis B: a meta-analysis. Antiviral Res. 2008;77(2):136-41. [pmid: 18078676].
Yeh CT, Sheen IS, Chen TC, Hsieh SY, Chu CM, Liaw YF. Olone modulates the therapeutic effect of interferon to eliminate preferentially the hepatitis B virus precore stop mutant. J Hepatol. 2000;32(5):829-36. [pmid: 10845671].
Yokosuka O, Omata M, Imazeki F, Hirota K, Mori J, Uchiumi K, et al. Combination of short-term prednisolone and adenine arabinoside in the treatment of chronic hepatitis B. A controlled study. Gastroenterology. 1985;89(2):246-51. [pmid: 4007415].
Yoo BC, Kim JH, Chung YH, Lee KS, Paik SW, Ryu SH, et al. Twenty-four-week clevudine therapy showed potent and sustained antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. 2007;45(5):1172-8. [pmid: 17464992].
Yoo BC, Kim JH, Kim TH, Koh KC, Um SH, Kim YS, et al. Clevudine is highly efficacious in hepatitis B e antigen-negative chronic hepatitis B with durable off-therapy viral suppression. Hepatology. 2007;46(4):1041-8. [pmid: 17647293].
You J, Zhuang L, Cheng HY, Yan SM, Qiao YW, Huang JH, et al. A randomized, controlled, clinical study of thymosin alpha-1 versus interferon-alpha in [corrected] patients with chronic hepatitis B lacking HBeAg in China [corrected]. [Erratum appears in J Chin Med Assoc. 2005; 68(3):154]. J Chin Med Assoc. 2005;68(2):65-72. [pmid: 15759817].
Zarski JP, Causse X, Cohard M, Cougnard J, Trepo C. A randomized, controlled trial of interferon alfa-2b alone and with simultaneous prednisone for the treatment of chronic hepatitis B. French Multicenter Group. J Hepatol. 1994;20(6):735-41. [pmid: 7930473].
Zavaglia C, Severini R, Tinelli C, Franzone JS, Airoldi A, Tempini S, et al. A randomized, controlled study of thymosin-alpha1 therapy in patients with anti-HBe, HBV-DNA-positive chronic hepatitis B. Dig Dis Sci. 2000;45(4):690-6. [pmid: 10759236].
Zheng MH, Shi KQ, Dai ZJ, Ye C, Chen YP. A 24-week, parallel-group, open-label, randomized clinical trial comparing the early antiviral efficacy of telbivudine and entecavir in the treatment of hepatitis B e antigen-positive chronic hepatitis B virus infection in adult Chinese patients. Clin Ther. 2010;32(4):649-58. [pmid: 20435234].

### Wrong Outcome

Alavian SM, Mansouri S, Abouzari M, Assari S, Bonab MS, Miri SM. Long-term efficacy of hepatitis B vaccination in healthcare workers of Oil Company Hospital, Tehran, Iran (1989-2005). Eur J Gastroenterol Hepatol. 2008;20(2):131-4. [pmid: 18188034].
Brooks EA, Lacey LF, Payne SL, Miller DW. Economic evaluation of lamivudine compared with interferon-alpha in the treatment of chronic hepatitis B in the United States. Am J Manag Care. 2001;7(7):677-82. [pmid: 11464426].
Brunetto MR, Giarin M, Saracco G, Oliveri F, Calvo P, Capra G, et al. Hepatitis B virus unable to secrete e antigen and response to interferon in chronic hepatitis B. Gastroenterology. 1993;105(3):845-50. [pmid: 7689519].
Butler LM, Mills PK, Yang RC, Chen MS Jr. Hepatitis B knowledge and vaccination levels in California Hmong youth: implications for liver Cancer prevention strategies. Asian Pac J Cancer Prev. 2005;6(3):401-3. [pmid: 16236007].
Carrouee-Durantel S, Durantel D, Werle-Lapostolle B, Pichoud C, Naesens L, Neyts J, et al. Suboptimal response to adefovir dipivoxil therapy for chronic hepatitis B in nucleoside-naive patients is not due to pre-existing drug-resistant mutants. Antivir Ther. 2008;13(3):381-8. [pmid: 18572751].
Chang ET, Sue E, Zola J, So SK. 3 For Life: a model pilot program to prevent hepatitis B virus infection and liver Cancer in Asian and Pacific Islander Americans. Am J Health Promot. 2009;23(3):176-81. [pmid: 19149422].
Chen MS Jr., Fang DM, Stewart SL, Ly MY, Lee S, Dang JH, et al. Increasing hepatitis B screening for hmong adults: results from a randomized controlled community-based study. Cancer Epidemiol Biomarkers Prev. 2013;22(5):782-91. [pmid: 23613027].
Cox AD, Cox D, Cyrier R, Graham-Dotson Y, Zimet GD. Can self-prediction overcome barriers to Hepatitis B vaccination? A randomized controlled trial. Health Psychol. 2012;31(1):97-105. [pmid: 21875205].
Degos F, Duhamel G, Brechot C, Nalpas B, Courouce AM, Tron F, et al. Hepatitis B vaccination in chronic alcoholics. J Hepatol. 1986;2(3):402-9. [pmid: 2941477].
Dufour A, Remis RS, Alary M, Otis J, Masse B, Turmel B, et al. Factors associated with hepatitis B vaccination among men having sexual relations with men in Montreal, Quebec, Canada. Omega Study Group. Sex Transm Dis. 1999;26(6):317-24. [pmid: 10417018].
Farrell M, Battersby M, Strang J. Screening for hepatitis B and vaccination of injecting drug users in NHS drug treatment services. Br J Addict. 1990;85(12):1657-9. [pmid: 2149662].
Foster T, Hon H, Kanwal F, Han S, Spiegel B. Screening high risk individuals for hepatitis B: physician knowledge, attitudes, and beliefs. Dig Dis Sci. 2011;56(12):3471-87. [pmid: 22001940].
Franson TR, Ksobiech LJ, Simonsen H. Prevalence of Hepatitis B carriers in a mental health in-patient facility: Implications for employee screening and vaccination. Psychiatr Hosp. Spr. 1986;17(2):81-3. [pmid: 10278763].
Gjeruldsen SR, Myrvang B, Opjordsmoen S. A 25-year follow-up study of drug addicts hospitalised for acute hepatitis: present and past morbidity. Eur Addict Res. 2003;9(2):80-6. [pmid: 12644734].
Gralnek IM, Hays RD, Kilbourne A, Rosen HR, Keeffe EB, Artinian L, et al. Development and evaluation of the Liver Disease Quality of Life instrument in persons with advanced, chronic liver disease--the LDQOL 1.0. Am J Gastroenterol. 2000;95(12):3552-65. [pmid: 11151892].
Grytdal SP, Liao Y, Chen R, Garvin CC, Grigg-Saito D, Kagawa-Singer M, et al. Hepatitis B testing and vaccination among Vietnamese- and Cambodian-Americans. J Community Health. 2009;34(3):173-80. [pmid: 19234773].
Gunn RA, Murray PJ, Ackers ML, Hardison WG, Margolis HS. Screening for chronic hepatitis B and C virus infections in an urban sexually transmitted disease clinic: rationale for integrating services. Sex Transm Dis. 2001;28(3):166-70. [pmid: 11289199].
Hagan H, Thiede H, McGough JP, Alexander ER. Hepatitis B vaccination among research participants, Seattle, Washington. Am J Public Health. 2002;92(11):1756. [pmid: 12406801].
Hagedorn H, Dieperink E, Dingmann D, Durfee J, Ho SB, Isenhart C, et al. Integrating hepatitis prevention services into a substance use disorder clinic. J Subst Abuse Treat. 2007;32(4):391-8. [pmid: 17481462].
Hamlyn E, McAllister J, Winston A, Sinclair B, Amin J, Carr A, et al. Is screening for sexually transmitted infections in men who have sex with men who receive non-occupational HIV post-exposure prophylaxis worthwhile?. [Erratum appears in Sex Transm Infect. 2006 ; 82(5):422]. Sex Transm Infect. 2006;82(1):21-3. [pmid: 16461596].
Hann HW, Han SH, Block TM, Harris M, Maa JF, Fisher RT, et al. Symptomatology and health attitudes of chronic hepatitis B patients in the USA. J Viral Hepat. 2008;15(1):42-51. [pmid: 18088244].
Hann HWL, Hann RS, Maddrey WC. Hepatitis B virus infection in 6,130 unvaccinated Korean-Americans surveyed between 1988 and 1990. Am J Gastroenterol. 2007;102(4):767-72. [pmid: 17397407].
Havel RD, Wright MP. Automated interviewing for hepatitis B risk assessment and vaccination referral. Am J Prev Med. 1997;13(5):392-5. [pmid: 9315273].
Hsu CE, Zhang G, Yan FA, Shang N, Le T. What made a successful hepatitis B program for reducing liver Cancer disparities: an examination of baseline characteristics and educational intervention, infection status, and missing responses of at-risk Asian Americans. J Community Health. 2010;35(3):325-35. [pmid: 20135208].
Hutchinson SJ, Wadd S, Taylor A, Bird SM, Mitchell A, Morrison DS, et al. Sudden rise in uptake of hepatitis B vaccination among injecting drug users associated with a universal Vaccine programme in prisons. Vaccine. 2004;23(2):210-4. [pmid: 15531039].
Hwang JP, Huang CH, Yi JK. Knowledge about hepatitis B and predictors of hepatitis B vaccination among Vietnamese American college students. J Am Coll Health. 2008;56(4):377-82. [pmid: 18316280].
Kim SY, Billah K, Lieu TA, Weinstein MC. Cost Effectiveness of Hepatitis B Vaccination at HIV Counseling and Testing Sites. Am J Prev Med. 2006;30(6):498-506. [pmid: 16704944].
Kose S, Turken M, Cavdar G, Tatar B, Senger SS. Evaluation of vaccination results in high-risk patients included in hepatitis B vaccination program. Human Vaccines. 2010;6(11):903-5. [pmid: 20980797].
Kumar A, Lalani S, Afridi AAK, Khuwaja AK. Screening of hepatitis B and C among people visiting general practice clinics in a rural district of Sindh, Pakistan. J Ayub Med Coll Abbottabad. 2010;22(4):143-5. [pmid: 22455283].
Kung AW, Jones BM, Lai CL. Effects of interferon-gamma therapy on thyroid function, T-lymphocyte subpopulations and induction of autoantibodies. J Clin Endocrinol Metab. 1990;71(5):1230-4. [pmid: 2121769].
Kweon YO, Goodman ZD, Dienstag JL, Schiff ER, Brown NA, Burchardt E, et al. Decreasing fibrogenesis: an immunohistochemical study of paired liver biopsies following lamivudine therapy for chronic hepatitis B. J Hepatol. 2001;35(6):749-55. [pmid: 11738102].
Lai CL, Lim SG, Brown NA, Zhou XJ, Lloyd DM, Lee YM, et al. A dose-finding study of once-daily oral telbivudine in HBeAg-positive patients with chronic hepatitis B virus infection. Hepatology. 2004;40(3):719-26. [pmid: 15349912].
Lampertico P, Manzin A, Rumi MG, Paolucci S, Del Ninno E, Clementi M, et al. Hepatitis B virus precore mutants in HBeAg carriers with chronic hepatitis treated with interferon. J Viral Hepat. 1995;2(5):251-6. [pmid: 8745317].
Li WC, Wang MR, Kong LB, Ren WG, Zhang YG, Nan YM. Peginterferon alpha-based therapy for chronic hepatitis B focusing on HBsAg clearance or seroconversion: a meta-analysis of controlled clinical trials. BMC Infect Dis. 2011;11:165. [pmid: 21651820].
Ma GX, Fang CY, Shive SE, Toubbeh J, Tan Y, Siu P. Risk perceptions and barriers to Hepatitis B screening and vaccination among Vietnamese immigrants. J Immigr Minor Health. 2007;9(3):213-20. [pmid: 17265128].
Ma GX, Gao W, Tan Y, Chae WG, Rhee J. A community-based participatory approach to a hepatitis B intervention for Korean Americans. Prog Community Health Partnersh. 2012;6(1):7-16. [pmid: 22643783].
Ma GX, Lee S, Wang M, Tan Y, Gao W, Ma X, et al. Role of sociocultural factors in hepatitis B screening among Asian Americans. South Med J. 2011;104(7):466-72. [pmid: 21886043].
Ma GX, Shive SE, Toubbeh JI, Tan Y, Wu D. Knowledge, attitudes, and behaviors of Chinese hepatitis B screening and vaccination. Am J Health Behav. 2008;32(2):178-87. [pmid: 18052858].
Ma SW, Li YY, Zhang GW, Huang X, Sun J, Li C, et al. Complementarity-determining region 3 size spectratypes of T cell receptor beta chains in CD8+ T cells following antiviral treatment of chronic hepatitis B. Antimicrob Agents Chemother. 2011;55(2):888-94. [pmid: 21098256].
Mahoney FJ, Stewart K, Hu H, Coleman P, Alter MJ. Progress toward the elimination of hepatitis B virus transmission among health care workers in the United States. Arch Intern Med. 1997;157(22):2601-5. [pmid: 9531229].
Margolis HS, Handsfield HH, Jacobs RJ, Gangi JE. Evaluation of office-based intervention to improve prevention counseling for patients at risk for sexually acquired hepatitis B virus infection. Hepatitis B-WARE Study Group. Am J Obstet Gynecol. 2000;182(1 Pt 1):1-6. [pmid: 10649147].
Marinho RT, Moura MC, Pedro M, Ramalho FJ, Velosa JF. Hepatitis B vaccination in hospital personnel and medical students. J Clin Gastroenterol. 1999;28(4):317-22. [pmid: 10372928].
Morimitsu Y, Kleiner DE Jr., Conjeevaram HS, Hsia CC, Di Bisceglie AM, Tabor E. Expression of transforming growth factor alpha in the liver before and after interferon alfa therapy for chronic hepatitis B. Hepatology. 1995;22(4 Pt 1):1021-6. [pmid: 7557846].
Moskovitz DN, Osiowy C, Giles E, Tomlinson G, Heathcote EJ. Response to long-term lamivudine treatment (up to 5 years) in patients with severe chronic hepatitis B, role of genotype and drug resistance. J Viral Hepat. 2005;12(4):398-404. [pmid: 15985011].
Muhlbacher A, Zdunek D, Melchior W, Michl U. Is infective blood donation missed without screening for antibody to hepatitis B core antigen and/or hepatitis B virus DNA?. Vox Sang. 2001;81(2):139. [pmid: 11555477].
Mustufa MA, Memon AA, Nasim S, Shahid A, Omar SM. Exposure to risk factors for hepatitis B and C viruses among primary school teachers in Karachi. J Infect Dev Ctries. 2010;4(10):616-20. [pmid: 21045353].
Nakazawa T, Shibuya A, Takeuchi A, Shibata Y, Hidaka H, Okuwaki Y, et al. Viral level is an indicator of long-term outcome of hepatitis B virus e antigen-negative carriers with persistently normal serum alanine aminotransferase levels. J Viral Hepat. 2011;18(7):e191-9. [pmid: 21692932].
Nam SW, Jung JJ, Bae SH, Choi JY, Yoon SK, Cho SH, et al. Clinical outcomes of delayed clearance of serum HBsAG in patients with chronic HBV infection. Korean J Intern Med. 2007;22(2):73-6. [pmid: 17616021].
Nguyen TT, McPhee SJ, Stewart S, Gildengorin G, Zhang L, Wong C, et al. Factors associated with hepatitis B testing among Vietnamese Americans. J Gen Intern Med. 2010;25(7):694-700. [pmid: 20306150].
Ozaras R, Tabak F, Tahan V, Ozturk R, Akin H, Mert A, et al. Correlation of quantitative assay of HBsAg and HBV DNA levels during chronic HBV treatment. Dig Dis Sci. 2008;53(11):2995-8. [pmid: 18409002].
Paik YH, Han KH, Hong SP, Lee HW, Lee KS, Kim SO, et al. The clinical impact of early detection of the YMDD mutant on the outcomes of long-term lamivudine therapy in patients with chronic hepatitis B. Antivir Ther. 2006;11(4):447-55. [pmid: 16856618].
Pal J, Czompoly T, Nyarady Z, Marczinovits I, Janaky T, Kele Z, et al. Determination of the fine epitope specificity of an anti-hepatitis B virus X protein monoclonal antibody using microanalytical and molecular biological methods. Mol Immunol. 2003;40(5):241-6. [pmid: 12943796].
Park GJH, Katelaris PH, Jones DB, Seow F, Lin BPC, Le Couteur DG, et al. The C-caffeine breath test distinguishes significant fibrosis in chronic hepatitis B and reflects response to lamivudine therapy. Aliment Pharmacol Ther. 2005;22(5):395-403. [pmid: 16128677].
Paul RG, Roodman ST, Campbell CR, Bodicky CJ, Perrillo RP. HLA class I antigen expression as a measure of response to antiviral therapy of chronic hepatitis B. Hepatology. 1991;13(5):820-5. [pmid: 2029988].
Petit MA, Zoulim F, Berthillon P, Capel F, Li J, Dauguet C, et al. PreS1 antigen/antibody patterns following interferon therapy in acute and chronic hepatitis B. J Hepatol. 1994;20(1):47-56. [pmid: 8201222].
Plaitano S, Sagliocca L, Mele A, Bove C, Protano D, Adamo B, et al. Hepatitis B mass immunization of adolescents: a pilot study in a community. Eur J Epidemiol. 1993;9(3):307-10. [pmid: 8405316].
Pollicino T, Isgro G, Di Stefano R, Ferraro D, Maimone S, Brancatelli S, et al. Variability of reverse transcriptase and overlapping S gene in hepatitis B virus isolates from untreated and lamivudine-resistant chronic hepatitis B patients. Antivir Ther. 2009;14(5):649-54. [pmid: 19704167].
Poynard T, Ngo Y, Marcellin P, Hadziyannis S, Ratziu V, Benhamou Y, et al. Impact of adefovir dipivoxil on liver fibrosis and activity assessed with biochemical markers (FibroTest-ActiTest) in patients infected by hepatitis B virus. J Viral Hepat. 2009;16(3):203-13. [pmid: 19175871].
Rein DB, Lesesne SB, Leese PJ, Weinbaum CM. Community-based hepatitis B screening programs in the United States in 2008. J Viral Hepat. 2010;17(1):28-33. [pmid: 19674286].
Robinson T, Bullen C, Humphries W, Hornell J, Moyes C. The New Zealand Hepatitis B Screening Programme: screening coverage and prevalence of chronic hepatitis B infection. N Z Med J. 2005;118(1211):U1345. [pmid: 15778747].
Scully LJ, Brown D, Lloyd C, Shein R, Thomas HC. Immunological studies before and during interferon therapy in chronic HBV infection: identification of factors predicting response. Hepatology. 1990;12(5):1111-7. [pmid: 1699861].
Sellors J, Zimic-Vincetic M, Howard M, Mahony JB, Chernesky MA. Predictors of positivity for hepatitis B and the derivation of a selective screening rule in a Canadian sexually transmitted disease clinic. J Clin Virol. 1998;11(1):85-91. [pmid: 9784147].
Shindo M, Hamada K, Nishioji K, Muramatsu A, Oda Y, Okuno T. The predictive value of liver fibrosis in determining the effectiveness of interferon and lamivudine therapies for chronic hepatitis B. J Gastroenterol. 2004;39(3):260-7. [pmid: 15065004].
Singal AK, Fontana RJ. Meta-analysis: oral anti-viral agents in adults with decompensated hepatitis B virus cirrhosis. Aliment Pharmacol Ther. 2012;35(6):674-89. [pmid: 22257108].
Spiegel BM, Bolus R, Han S, Tong M, Esrailian E, Talley J, et al. Development and validation of a disease-targeted quality of life instrument in chronic hepatitis B: the hepatitis B quality of life instrument, version 1.0. Hepatology. 2007;46(1):113-21. [pmid: 17596882].
Svirtlih N, Pavic S, Terzic D, Delic D, Simonovic J, Gvozdenovic E, et al. Reduced quality of life in patients with chronic viral liver disease as assessed by SF12 questionnaire. J Gastrointestin Liver Dis. 2008;17(4):405-9. [pmid: 19104701].
Tan NC, Cheah SL, Teo EK, Yang LH. Patients with chronic hepatitis B infection: what is their quality of life?. Singapore Med J. 2008;49(9):682-7. [pmid: 18830541].
Tenney DJ, Rose RE, Baldick CJ, Pokornowski KA, Eggers BJ, Fang J, et al. Long-term monitoring shows hepatitis B virus resistance to entecavir in nucleoside-naive patients is rare through 5 years of therapy. Hepatology. 2009;49(5):1503-14. [pmid: 19280622].
ter Borg MJ, van Zonneveld M, Zeuzem S, Senturk H, Akarca US, Simon C, et al. Patterns of viral decline during PEG-interferon alpha-2b therapy in HBeAg-positive chronic hepatitis B: relation to treatment response. Hepatology. 2006;44(3):721-7. [pmid: 16941701].
van der Eijk AA, Niesters HG, Hansen BE, Heijtink RA, Janssen HL, Schalm SW, et al. Quantitative HBV DNA levels as an early predictor of nonresponse in chronic HBe-antigen positive hepatitis B patients treated with interferon-alpha. J Viral Hepat. 2006;13(2):96-103. [pmid: 16436127].
van der Plas SM, Hansen BE, de Boer JB, Stijnen T, Passchier J, de Man RA, et al. The Liver Disease Symptom Index 2.0; validation of a disease-specific questionnaire. Qual Life Res. 2004;13(8):1469-81. [pmid: 15503842].
van der Sande MAB, Waight PA, Mendy M, Zaman S, Kaye S, Sam O, et al. Long-term protection against HBV chronic carriage of Gambian adolescents vaccinated in infancy and immune response in HBV booster trial in adolescence. PLoS ONE. 2007;2(8):e753. [pmid: 17710152].
Villa E, Lei B, Taliani G, Graziosi A, Critelli R, Luongo M, et al. Pretreatment with pegylated interferon prevents emergence of lamivudine mutants in lamivudine-naive patients: a pilot study. Antivir Ther. 2009;14(8):1081-7. [pmid: 20032538].
Wai CT, Chu CJ, Hussain M, Lok AS. HBV genotype B is associated with better response to interferon therapy in HBeAg(+) chronic hepatitis than genotype C. Hepatology. 2002;36(6):1425-30. [pmid: 12447868].
Westh H, Hoffmann S, Christiansen E, Worm AM. Hepatitis B core antibody screening in a high prevalence group: comparison of three enzyme immunoassays using receiver operating characteristic analysis. J Virol Methods. 1996;56(1):13-8. [pmid: 8690761].
Westland CE, Yang H, Delaney WEt, Gibbs CS, Miller MD, Wulfsohn M, et al. Week 48 resistance surveillance in two phase 3 clinical studies of adefovir dipivoxil for chronic hepatitis B. Hepatology. 2003;38(1):96-103. [pmid: 12829991].
Williams SJ, Farrell GC. Serial antipyrine clearance studies detect altered hepatic metabolic function during spontaneous and interferon-induced changes in chronic hepatitis B disease activity. Hepatology. 1989;10(2):192-7. [pmid: 2744731].
Wong VWS, Wong GLH, Chim AML, Choi PCL, Chan AWH, Tsang SWC, et al. Surrogate end points and long-term outcome in patients with chronic hepatitis B. Clin Gastroenterol Hepatol. 2009;7(10):1113-20. [pmid: 19500693].
Yeh CT, Sheen IS, Chen TC, Hsieh SY, Chu CM, Liaw YF. Prednisolone modulates the therapeutic effect of interferon to eliminate preferentially the hepatitis B virus precore stop mutant. J Hepatol. 2000;32(5):829-36. [pmid: 10845671].
Yen YH, Lu SN, Chen CH, Wang JH, Wu CM, Hung CH, et al. Changes in serum hepatitis B e antigen (HBeAg) levels associated with the emergence of YMDD mutants in HBeAg non-seroconverted patients during lamivudine therapy. Liver Int. 2007;27(10):1349-55. [pmid: 18036099].
Younossi ZM, Guyatt G, Kiwi M, Boparai N, King D. Development of a disease specific questionnaire to measure health related quality of life in patients with chronic liver disease. Gut. 1999;45(2):295-300. [pmid: 10403745].
Yuen MF, Hui CK, Cheng CC, Wu CH, Lai YP, Lai CL. Long-term follow-up of interferon alfa treatment in Chinese patients with chronic hepatitis B infection: The effect on hepatitis B e antigen seroconversion and the development of cirrhosis-related complications. Hepatology. 2001;34(1):139-45. [pmid: 11431745].
Zhao H, Kurbanov F, Wan MB, Yin YK, Niu JQ, Hou JL, et al. Genotype B and younger patient age associated with better response to low-dose therapy: a trial with pegylated/nonpegylated interferon-alpha-2b for hepatitis B e antigen-positive patients with chronic hepatitis B in China. Clin Infect Dis. 2007;44(4):541-8. [pmid: 17243057].

### Wrong Study Design for Key Question

Amin J, Dore GJ, O'Connell DL, Bartlett M, Tracey E, Kaldor JM, et al. Cancer incidence in people with hepatitis B or C infection: a large community-based linkage study. J Hepatol. 2006;45(2):197-203. [pmid: 16684579].
Asahina Y, Izumi N, Uchihara M, Noguchi O, Nishimura Y, Inoue K, et al. Core promoter/pre-core mutations are associated with lamivudine-induced HBeAg loss in chronic hepatitis B with genotype C. J Hepatol. 2003;39(6):1063-9. [pmid: 14642627].
Bayraktar Y, Koseoglu T, Somner C, Kayhan B, Temizer A, Uzunalimoglu B, et al. The use of deferoxamine infusions to enhance the response rate to interferon-alpha treatment of chronic viral hepatitis B. J Viral Hepat. 1996;3(3):129-35. [pmid: 8871871].
Bolukbas C, Bolukbas FF, Kendir T, Akbayir N, Ince AT, Abut E, et al. The effectiveness of lamivudine treatment in cirrhotic patients with HBV precore mutations: a prospective, open-label study. Dig Dis Sci. 2006;51(7):1196-202. [pmid: 16944009].
Brunetto MR, Oliveri F, Coco B, Leandro G, Colombatto P, Gorin JM, et al. Outcome of anti-HBe positive chronic hepatitis B in alpha-interferon treated and untreated patients: a long term cohort study. J Hepatol. 2002;36(2):263-70. [pmid: 11830339].
Chang TT, Lai CL, Kew Yoon S, Lee SS, Coelho HS, Carrilho FJ, et al. Entecavir treatment for up to 5 years in patients with hepatitis B e antigen-positive chronic hepatitis B. Hepatology. 2010;51(2):422-30. [pmid: 20049753].
Chen G, Lin W, Shen F, Iloeje UH, London WT, Evans AA. Chronic hepatitis B virus infection and mortality from non-liver causes: results from the Haimen City cohort study. Int J Epidemiol. 2005;34(1):132-7. [pmid: 15659459].
Chen G, Lin W, Shen F, Iloeje UH, London WT, Evans AA. Past HBV viral load as predictor of mortality and morbidity from HCC and chronic liver disease in a prospective study. Am J Gastroenterol. 2006;101(8):1797-803. [pmid: 16817842].
Cianciara J, Laskus T. Development of transient autoimmune hepatitis during interferon treatment of chronic hepatitis B. Dig Dis Sci. 1995;40(8):1842-4. [pmid: 7648989].
Crook PD, Jones ME, Hall AJ. Mortality of hepatitis B surface antigen-positive blood donors in England and Wales. Int J Epidemiol. 2003;32(1):118-24. [pmid: 12690022].
Da Villa G, Piccinino F, Scolastico C, Fusco M, Piccinino R, Sepe A. Long-term epidemiological survey of hepatitis B virus infection in a hyperendemic area (Afragola, southern Italy): results of a pilot vaccination project. Res Virol. 1998;149(5):263-70. [pmid: 9879603].
Dakin H, Bentley A, Dusheiko G. Cost-utility analysis of tenofovir disoproxil fumarate in the treatment of chronic hepatitis B. Value Health. 2010;13(8):922-33. [pmid: 20825619].
Dakin H, Fidler C, Harper C. Mixed treatment comparison meta-analysis evaluating the relative efficacy of nucleos(t)ides for treatment of nucleos(t)ide-naive patients with chronic hepatitis B. Value Health. 2010;13(8):934-45. [pmid: 20825624].
di Marco V, di Stefano G, Ferraro D, Almasio P, Bonura C, Giglio M, et al. HBV-DNA suppression and disease course in HBV cirrhosis patients on long-term lamivudine therapy. Antivir Ther. 2005;10(3):431-9. [pmid: 15918334].
Dienstag JL, Goldin RD, Heathcote EJ, Hann HW, Woessner M, Stephenson SL, et al. Histological outcome during long-term lamivudine therapy. Gastroenterology. 2003;124(1):105-17. [pmid: 12512035].
Dienstag JL, Wei LJ, Xu D, Kreter B. Cross-study analysis of the relative efficacies of oral antiviral therapies for chronic hepatitis B infection in nucleoside-naive patients. Clin Drug Investig. 2007;27(1):35-49.
Eun JR, Lee HJ, Kim TN, Lee KS. Risk assessment for the development of hepatocellular carcinoma: according to on-treatment viral response during long-term lamivudine therapy in hepatitis B virus-related liver disease. J Hepatol. 2010;53(1):118-25. [pmid: 20471129].
Evans AA, Chen G, Ross EA, Shen FM, Lin WY, London WT. Eight-year follow-up of the 90,000-person Haimen City cohort: I. Hepatocellular carcinoma mortality, risk factors, and gender differences. Cancer Epidemiol Biomarkers Prev. 2002;11(4):369-76. [pmid: 11927497].
Fornaciari G, Bassi C, Beltrami M, Castagnetti E, Maccari S, Plancher AC. Hemolytic anemia secondary to interferon treatment for chronic B hepatitis. J Clin Gastroenterol. 1991;13(5):596-7. [pmid: 1744407].
Gaia S, Marzano A, Smedile A, Barbon V, Abate ML, Olivero A, et al. Four years of treatment with lamivudine: clinical and virological evaluations in HBe antigen-negative chronic hepatitis B. Aliment Pharmacol Ther. 2004;20(3):281-7. [pmid: 15274664].
Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, Chang TT, Kitis G, Rizzetto M, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B for up to 5 years. Gastroenterology. 2006;131(6):1743-51. [pmid: 17087951].
Hutton DW, Tan D, So SK, Brandeau ML. Cost-effectiveness of screening and vaccinating Asian and Pacific Islander adults for hepatitis B. Ann Intern Med. 2007;147(7):460-9. [pmid: 17909207].
Hwang JP, Mohseni M, Gor BJ, Wen S, Guerrero H, Vierling JM. Hepatitis B and hepatitis C prevalence and treatment referral among Asian Americans undergoing community-based hepatitis screening. Am J Public Health. Suppl 1. 2010;100:S118-24. [pmid: 20147697].
Hynicka LM, Yunker N, Patel PH. A review of oral antiretroviral therapy for the treatment of chronic hepatitis B. Ann Pharmacother. 2010;44(7-8):1271-86. [pmid: 20587747].
Ikeda K, Saitoh S, Suzuki Y, Kobayashi M, Tsubota A, Fukuda M, et al. Interferon decreases hepatocellular Carcinogenesis in patients with cirrhosis caused by the hepatitis B virus: a pilot study. Cancer. 1998;82(5):827-35. [pmid: 9486570].
International Interferon-alpha Hepatocellular Carcinoma Study Group. Effect of interferon-alpha on progression of cirrhosis to hepatocellular carcinoma: a retrospective cohort study. International Interferon-alpha Hepatocellular Carcinoma Study Group. [Erratum appears in Lancet 1998; 352(9135):1230]. Lancet. 1998;351(9115):1535-9. [pmid: 10326535].
Kaiser T, Moessner J, Patel K, McHutchison JG, Tillmann HL. Life threatening liver disease during treatment with monoclonal antibodies. BMJ. 2009;338:b508. [pmid: 19224957].
Kaymakoglu S, Danalioglu A, Demir K, Karaca C, Akyuz F, Onel D, et al. Long-Term Results of Interferon Alpha Monotherapy in Patients with HBeAg-Negative Chronic Hepatitis B. Dig Dis Sci. 2007;52(3):727-31. [pmid: 17237999].
Kurihara T, Imazeki F, Yokosuka O, Fukai K, Kanda T, Kawai S, et al. Effect of lamivudine in HBeAg-positive chronic hepatitis B: discordant effect on HBeAg and HBV DNA according to pretreatment ALT level. World J Gastroenterol. 2005;11(22):3346-50. [pmid: 15948237].
Lai CL, Yuen MF. Prevention of hepatitis b virus-related hepatocellular carcinoma with antiviral therapy. Hepatology. 2013;57(1):399-408. [pmid: 22806323].
Lin SM, Yu ML, Lee CM, Chien RN, Sheen IS, Chu CM, et al. Interferon therapy in HBeAg positive chronic hepatitis reduces progression to cirrhosis and hepatocellular carcinoma. J Hepatol. 2007;46(1):45-52. [pmid: 17107734].
Lok AS, McMahon BJ. Chronic hepatitis B. Hepatology. 2007;45(2):507-39. [pmid: 17256718].
Lugoboni F, Migliozzi S, Mezzelani P, Pajusco B, Ceravolo R, Quaglio G. Progressive decrease of hepatitis B in a cohort of drug users followed over a period of 15 years: the impact of anti-HBV vaccination. Scand J Infect Dis. 2004;36(2):131-3. [pmid: 15061668].
Manesis EK, Hadziyannis SJ. Interferon α Treatment and Retreatment of Hepatitis B e Antigen-Negative Chronic Hepatitis B. Gastroenterology. 2001;121(1):101-9. [pmid: 11438498].
Manesis EK, Moschos M, Brouzas D, Kotsiras J, Petrou C, Theodosiadis G, et al. Neurovisual impairment: a frequent complication of alpha-interferon treatment in chronic viral hepatitis. Hepatology. 1998;27(5):1421-7. [pmid: 9581701].
Manolakopoulos S, Bethanis S, Elefsiniotis J, Karatapanis S, Triantos C, Sourvinos G, et al. Lamivudine monotherapy in HBeAg-negative chronic hepatitis B: prediction of response-breakthrough and long-term clinical outcome. Aliment Pharmacol Ther. 2006;23(6):787-95. [pmid: 16556181].
Marcellin P, Gane E, Buti M, Afdhal N, Sievert W, Jacobson IM, et al. Regression of cirrhosis during treatment with tenofovir disoproxil fumarate for chronic hepatitis B: a 5-year open-label follow-up study. Lancet. 2013;381(9865):468-75. [pmid: 23234725].
Marino D, Boso C, Crivellari G, Mazzarotto R, Stragliotto S, Farinati F, et al. Fatal HBV-related liver failure during lamivudine therapy in a patient with non-Hodgkin's lymphoma. Tumori. 2008;94(5):748-9. [pmid: 19112953].
Matsumoto A, Tanaka E, Rokuhara A, Kiyosawa K, Kumata H, Omata M, et al. Efficacy of lamivudine for preventing hepatocellular carcinoma in chronic hepatitis B: a multicenter retrospective study of 2795 patients. Hepatol Res. 2005;32(1):173-84. [pmid: 16024289].
Mauracher E. Low dose interferon alfa-2b for chronic hepatitis B in Asian countries. Gut. 1993;34(2 Suppl):S99-100. [pmid: 8314500].
McKenzie R, Fried MW, Sallie R, Conjeevaram H, Di Bisceglie AM, Park Y, et al. Hepatic failure and lactic acidosis due to fialuridine (FIAU), an investigational nucleoside analogue for chronic hepatitis B. N Engl J Med. 1995;333(17):1099-105. [pmid: 7565947].
McMahon BJ, Alberts SR, Wainwright RB, Bulkow L, Lanier AP. Hepatitis B-related sequelae. Prospective study in 1400 hepatitis B surface antigen-positive Alaska native carriers. Arch Intern Med. 1990;150(5):1051-4. [pmid: 2158773].
McMahon BJ, Alward WL, Hall DB, Heyward WL, Bender TR, Francis DP, et al. Acute hepatitis B virus infection: relation of age to the clinical expression of disease and subsequent development of the carrier state. J Infect Dis. 1985;151(4):599-603. [pmid: 3973412].
McMahon BJ, Bulkow LR, Singleton RJ, Williams J, Snowball M, Homan C, et al. Elimination of hepatocellular carcinoma and acute hepatitis B in children 25 years after a hepatitis B newborn and catch-up immunization program. Hepatology. 2011;54(3):801-7. [pmid: 21618565].
McMahon BJ, Holck P, Bulkow L, Snowball M. Serologic and clinical outcomes of 1536 Alaska Natives chronically infected with hepatitis B virus. Ann Intern Med. 2001;135(9):759-68. [pmid: 11694101].
Milkiewicz P, Yim C, Pache I, Heathcote J. Diffuse skin reaction in patient with hepatitis B, treated with two different formulations of pegylated interferon. Can J Gastroenterol. 2005;19(11):677-8. [pmid: 16292363].
Miranda-Guardiola F, Fernandez-Llama P, Badia JR, Botey A, Estruch R, Darnell A, et al. Acute renal failure associated with alpha-interferon therapy for chronic hepatitis B. Nephrol Dial Transplant. 1995;10(8):1441-3. [pmid: 8538940].
Miyake Y, Kobashi H, Yamamoto K. Meta-analysis: the effect of interferon on development of hepatocellular carcinoma in patients with chronic hepatitis B virus infection. J Gastroenterol. 2009;44(5):470-5. [pmid: 19308310].
Muqit MKM, Stanga PE, Vilar FJ, Patton N. Presumed entecavir-induced ocular toxicity. Eye (Lond). 2011;25(12):1665-8. [pmid: 22020173].
Murakami CS, Zeller K, Bodenheimer HC Jr., Lee WM. Idiopathic thrombocytopenic purpura during interferon-alpha 2B treatment for chronic hepatitis. Am J Gastroenterol. 1994;89(12):2244-5. [pmid: 7977252].
Nevens F, Goubau P, Van Eyken P, Desmyter J, Desmet V, Fevery J. Treatment of decompensated viral hepatitis B-induced cirrhosis with low doses of interferon alpha. Liver. 1993;13(1):15-9. [pmid: 8455421].
Nishizaki Y, Morizane T, Kojima S, Sakuma K, Koyama A, Shiozawa H, et al. Predictive factors for the response to lamivudine in HBV-infected patients with chronic hepatitis and cirrhosis. Tokai J Exp Clin Med. 2006;31(3):121-4. [pmid: 21302238].
Ojetti V, Gasbarrini A, Migneco A, Flore R, Santoliquido A, De Martini D, et al. Lamivudine-induced muscle mitochondrial toxicity. Dig Liver Dis. 2002;34(5):384-5. [pmid: 12118960].
Papatheodoridis GV, Dimou E, Dimakopoulos K, Manolakopoulos S, Rapti I, Kitis G, et al. Outcome of hepatitis B e antigen-negative chronic hepatitis B on long-term nucleos(t)ide analog therapy starting with lamivudine. Hepatology. 2005;42(1):121-9. [pmid: 15962291].
Papatheodoridis GV, Petraki K, Cholongitas E, Kanta E, Ketikoglou I, Manesis EK. Impact of interferon-alpha therapy on liver fibrosis progression in patients with HBeAg-negative chronic hepatitis B. J Viral Hepat. 2005;12(2):199-206. [pmid: 15720536].
Perrillo R, Tamburro C, Regenstein F, Balart L, Bodenheimer H, Silva M, et al. Low-dose, titratable interferon alfa in decompensated liver disease caused by chronic infection with hepatitis B virus. Gastroenterology. 1995;109(3):908-16. [pmid: 7657121].
Piao CY, Fujioka Si, Iwasaki Y, Fujio K, Kaneyoshi T, Araki Y, et al. Lamivudine treatment in patients with HBV-related hepatocellular carcinoma--using an untreated, matched control cohort. Acta Med Okayama. 2005;59(5):217-24. [pmid: 16286955].
Porres JC, Carreno V, Ruiz M, Marron JA, Bartolome J. Interferon antibodies in patients with chronic HBV infection treated with recombinant interferon. J Hepatol. 1989;8(3):351-7. [pmid: 2732449].
Poynard T, Zoulim F, Ratziu V, Degos F, Imbert-Bismut F, Deny P, et al. Longitudinal assessment of histology surrogate markers (FibroTest-ActiTest) during lamivudine therapy in patients with chronic hepatitis B infection. Am J Gastroenterol. 2005;100(9):1970-80. [pmid: 16128941].
Salkic N, Zerem E, Zildzic M, Basic M. Reversible peg-interferon-induced unilateral sensorineural hearing loss during hepatitis B treatment. Turk J Gastroenterol. 2009;20(2):156. [pmid: 19530055].
Sata M, Yano Y, Yoshiyama Y, Ide T, Kumashiro R, Suzuki H, et al. Mechanisms of thrombocytopenia induced by interferon therapy for chronic hepatitis B. J Gastroenterol. 1997;32(2):206-10. [pmid: 9085169].
Schalm SW, Summerskill WH, Gitnick GL, Elveback LR. Contrasting features and responses to treatment of severe chronic active liver disease with and without hepatitis BS antigen. Gut. 1976;17(10):781-6. [pmid: 793956].
Senturk H, Baysal B, Tahan V, Zerdali H, Ozaras R, Tabak F, et al. Long-Term Effect of Interferon Therapy in Patients with HBeAg Positive Chronic Hepatitis B Infection. Dig Dis Sci. 2011/01/01. 2011;56(1):208-12. [pmid: 20467899].
Shakil AO, Di Bisceglie AM, Hoofnagle JH. Seizures during alpha interferon therapy. J Hepatol. 1996;24(1):48-51. [pmid: 8834024].
Sun LJ, Yu JW, Zhao YH, Kang P, Li SC. Influential factors of prognosis in lamivudine treatment for patients with acute-on-chronic hepatitis B liver failure. J Gastroenterol Hepatol. 2010;25(3):583-90. [pmid: 19968744].
Tassopoulos NC, Papaevangelou GJ, Sjogren MH, Roumeliotou-Karayannis A, Gerin JL, Purcell RH. Natural history of acute hepatitis B surface antigen-positive hepatitis in Greek adults. Gastroenterology. 1987;92(6):1844-50. [pmid: 3569758].
Thio CL, Seaberg EC, Skolasky R Jr., Phair J, Visscher B, Munoz A, et al. HIV-1, hepatitis B virus, and risk of liver-related mortality in the Multicenter Cohort Study (MACS). Lancet. 2002;360(9349):1921-6. [pmid: 12493258].
Thomas HC, Karayiannis P, Brook G. Treatment of hepatitis B virus infection with interferon. Factors predicting response to interferon. J Hepatol. 1991;13(1).
Van Thiel DH, Friedlander L, Fagiuoli S, Wright HI, Irish W, Gavaler JS. Response to interferon alpha therapy is influenced by the iron content of the liver. J Hepatol. 1994;20(3):410-5. [pmid: 8014455].
Wong GLH, Yiu KKL, Wong VWS, Tsoi KKF, Chan HLY. Meta-analysis: reduction in hepatic events following interferon-alfa therapy of chronic hepatitis B. Aliment Pharmacol Ther. 2010;32(9):1059-68. [pmid: 20807216].
Woo G, Tomlinson G, Nishikawa Y, Kowgier M, Sherman M, Wong DKH, et al. Tenofovir and entecavir are the most effective antiviral agents for chronic hepatitis B: a systematic review and Bayesian meta-analyses. Gastroenterology. 2010;139(4):1218-29. [pmid: 20600036].
Wu CF, Yu MW, Lin CL, Liu CJ, Shih WL, Tsai KS, et al. Long-term tracking of hepatitis B viral load and the relationship with risk for hepatocellular carcinoma in men. Carcinogenesis. 2008;29(1):106-12. [pmid: 17999990].
Yang YF, Zhao W, Zhong YD, Xia HM, Shen L, Zhang N. Interferon therapy in chronic hepatitis B reduces progression to cirrhosis and hepatocellular carcinoma: a meta-analysis. J Viral Hepat. 2009;16(4):265-71. [pmid: 19220736].
Yu MW, Yeh SH, Chen PJ, Liaw YF, Lin CL, Liu CJ, et al. Hepatitis B virus genotype and DNA level and hepatocellular carcinoma: a prospective study in men. J Natl Cancer Inst. 2005;97(4):265-72. [pmid: 15713961].
Yuen MF, Yuan HJ, Wong DK, Yuen JC, Wong WM, Chan AO, et al. Prognostic determinants for chronic hepatitis B in Asians: therapeutic implications. Gut. 2005;54(11):1610-4. [pmid: 15871997].
Yuen MF, Sablon E, Libbrecht E, Van De Velde H, Wong DKH, Fung J, et al. Significance of viral load, core promoter/precore mutations and specific sequences of polymerase gene in HBV-infected patients on 3-year lamivudine treatment. Antivir Ther. 2006;11(6):779-86. [pmid: 17310822].
Zeng M, Yimin M, Guangbi Y, Jinlin H, Hao W, Hong R, et al. Five years of treatment with adefovir dipivoxil in Chinese patients with HBeAg-positive chronic hepatitis B. Liver Int. 2012;32(1):137-46. [pmid: 22097972].
Zhao S, Tang L, Fan X, Chen L. Telbivudine for chronic hepatitis B. Cochrane Database Syst Rev. 2010;(9).
Zhao SH, Liu EQ, Cheng DX, Li YF, Wang YL, Chen YL, et al. Comparison of entecavir and adefovir for the treatment of chronic hepatitis B. Braz J Infect Dis. 2012;16(4):366-72. [pmid: 22846126].
Schiano TD, Lissoos TW, Ahmed A, Siano C, Zaitman D, Cohn G, et al. Lamivudine-stavudine-induced liver failure in hepatitis B cirrhosis. Am J Gastroenterol. 1997;92(9):1563-4. [pmid: 9317091].
Dogan UB, Kara B, Gumurdulu Y, Soylu A, Akin MS. Comparison of the efficacy of tenofovir and entecavir for the treatment of nucleos(t)ide-naive patients with chronic hepatitis B. Turk J Gastroenterol. 2012;23(3):247-52. [pmid: 22798114].

### Wrong Publication Type

Bouchard MJ, Navas-Martin S. Hepatitis B and C virus hepatoCarcinogenesis: lessons learned and future challenges. Cancer Lett. 2011;305(2):123-43. [pmid: 21168955].
Brahams D. Deaths in US fialuridine trial. Lancet. 1994;343(8911):1494-5. [pmid: 7911188].
Buffington J, Mast EE. Prevaccination screening for hepatitis B among sexually active adolescents and young adults. Clin Infect Dis. 1998;27(6):1562-3. [pmid: 9868699].
Busch MP, Kleinman SH, Nemo GJ. Current and emerging infectious risks of blood transfusions. JAMA. 2003;289(8):959-62. [pmid: 12597733].
Chien RN, Liaw YF. Nucleos(t)ide analogues for hepatitis B virus: strategies for long-term success. Best Pract Res Clin Gastroenterol. 2008;22(6):1081-92. [pmid: 19187868].
De Clercq E. The discovery of antiviral agents: ten different compounds, ten different stories. Med Res Rev. 2008;28(6):929-53. [pmid: 18438800].
Eun JR, Lee HJ, Lee S, Kim TN, Jang BIK, Choi JW, et al. The effect of lamivudine and adefovir dipivoxil on preventing hepatocellular carcinoma in HBV-related liver cirrhosis. Hepatology. 2007;46:664A-5A.
Fung J, Ching-Lung L, Seto WK, Yuen MF. Nucleoside/nucleotide analogues in the treatment of chronic hepatitis B. J Antimicrob Chemother. 2011;66:2715-25. [pmid: 21965435].
Gentilcore E, Marzano A, Smedile A, Rizzetto M. Ineffectiveness of hepatitis B vaccination in lamivudine-treated cirrhotics. J Hepatol. 2004;40(2):357-8. [pmid: 14739114].
Ghany M, Liang TJ. Drug targets and molecular mechanisms of drug resistance in chronic hepatitis B. Gastroenterology. 2007;132(4):1574-85. [pmid: 17408658].
Gish RG, Gadano AC. Chronic hepatitis B: current epidemiology in the Americas and implications for management. J Viral Hepat. 2006;13(12):787-98. [pmid: 17109678].
Grady GF. Strategies for prevention of hepatitis B as a sexually transmitted disease. Sex Transm Dis. 1981;8(4 suppl):344-8. [pmid: 6800042].
Grime P. Blood-borne virus screening in health care workers: Is it worthwhile?. Occup Med. 2007;57(8):544-6.
Hadziyannis SJ. Lymphoblastoid interferon in controlled trials of chronic hepatitis B virus infection. Hepatology. 1988;8(3):696-8. [pmid: 3286465].
Herzenberg H. Interferon alfa-2b for chronic hepatitis B. N Engl J Med. 1991;324(7):493-4. [pmid: 2025320].
Hoofnagle JH, Doo E, Liang TJ, Fleischer R, Lok AS. Management of hepatitis B: summary of a clinical research workshop. Hepatology. 2007;45(4):1056-75. [pmid: 17393513].
Ibrahim N, Yaseen AlSabbagh EM, Qintar M, Samra M, Shahrour Y. Interferon beta for chronic hepatitis B. Cochrane Database Syst Rev. 2010;(6).
Imanishi J, Kishida T. Clinical trials with interferon in Japan. Tex Rep Biol Med. 1981;41:647-52. [pmid: 6189229].
Liaw YF. Impact of hepatitis B therapy on the long-term outcome of liver disease. Liver Int. Suppl 1. 2011;31:117-21. [pmid: 21205148].
Liaw YF, Lin SM, Sheen IS, Chen TJ, Chu CM. Treatment of chronic type B hepatitis in Southeast Asia. Am Med J. 1988;85(2A):147-9.
Lok ASF, Lai CL, Wu PC, Lau JY, Leung EK, Wong LS. Treatment of chronic hepatitis B with interferon: experience in Asian patients. Semin Liver Dis. 1989;9(4):249-53. [pmid: 2690348].
Martelli CM, Turchi M, Souto FJ, Saez-Alquezar A, Andrade AL, Zicker F. Anti-HBc testing for blood donations in areas with intermediate hepatitis B endemicity. Pan American Journal of Public Health. 1999;6(1):69-73. [pmid: 10446516].
Muller R, Baumgarten R, Markus R, Schulz M, Wittenberg H, Hintsche-Kilger B, et al. Low dose alpha interferon treatment in chronic hepatitis B virus infection. Gut. 1993;34(2 Suppl):S97-8. [pmid: 8314499].
Mumtaz K, Hamid S, Jafri W. Pegylated interferon for chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).
Mumtaz K, Khan HS, Bhatti IO, Hamid S, Jafri W. Interferon alpha for chronic hepatitis B. Cochrane Database Syst Rev. 2010;(6).
Mumtaz K, Subhan A, Hamid S, Jafri W. Lamivudine for chronic hepatitis B in adults. Cochrane Database Syst Rev. 2009;(1).
Murofushi T, Takeuchi N, Ozeki H, Mizuno M. Acute vestibular dysfunction associated with interferon-alpha therapy. Eur Arch Otorhinolaryngol. 1998;255(2):77-8. [pmid: 9550261].
Njei B, Kumar S, Kongnyuy EJ. Adefovir dipivoxil versus other antiviral drugs for chronic hepatitis B. Cochrane Database Syst Rev. 2011;(12).
Njei B, Kumar S, Kongnyuy EJ. Adefovir dipivoxil for chronic hepatitis B. Cochrane Database Syst Rev. 2011;(12).
Pablo K, Rooks P, Nevin R. Benefits of serologic screening for hepatitis B immunity in military recruits. J Infect Dis. 2005;192(12):2180-1. author reply 1. [pmid: 16288386].
Perez-Roldan F, Gonzalez-Carro P, Villafanez-Garcia MC. Adefovir dipivoxil for chemotherapy-induced activation of hepatitis B virus infection. N Engl J Med. 2005;352(3):310-1. [pmid: 15659742].
Propst A, Propst T, Dietze O, Kathrein H, Judmeier G, Vogel W. Development of granulomatous hepatitis during treatment with interferon-alpha 2b. Dig Dis Sci. 1995;40(10):2117-8. [pmid: 7587776].
Puliyel JM, Taneja V, Jindal K, Thomas N. Hepatitis B leading to hepatocellular carcinoma: calculating the risk. Indian J Gastroenterol. 2001;20(6):251-2. [pmid: 11817790].
Quaglio G, Lugoboni F, Mezzelani P, Des Jarlais DC, Lechi A. Hepatitis vaccination among drug users. Vaccine. 2006;24(15):2702-9. [pmid: 16436307].
Rizzetto M, Volpes R, Smedile A. Response of pre-core mutant chronic hepatitis B infection to lamivudine. J Med Virol. 2000;61(3):398-402. [pmid: 10861653].
Rizzetto M, Zanetti AR. Progress in the prevention and control of viral hepatitis type B: closing remarks. J Med Virol. 2002;67(3):463-6. [pmid: 12116047].
Seeff LB, Beebe GW, Hoofnagle JH, Norman JE, Buskell-Bales Z, Waggoner JG, et al. A serologic follow-up of the 1942 epidemic of post-vaccination hepatitis in the United States Army. N Engl J Med. 1987;316(16):965-70. [pmid: 2436048].
Tron F, Hepatitis B. Vaccine: clinical experience. IARC Sci Publ. 1984;(63):279-95. [pmid: 6242147].
van der Veen YJJ, de Zwart O, Mackenbach J, Richardus JH. Cultural tailoring for the promotion of hepatitis B screening in Turkish Dutch: a protocol for a randomized controlled trial. BMC Public Health. 2010;10:674. [pmid: 21054830].
Weimar W, Heijtink RA, Schalm SW, van Blankenstein M, Schellekens H, Masurel N, et al. Fibroblast interferon in HBsAg-positive chronic active hepatitis. Lancet. 1977;2(8051):1282. [pmid: 73970].
Woo GW, Krahn M, Prichett S. Entecavir for chronic hepatitis B. Cochrane Database Syst Rev. 2009;(1).

### Wrong Comparison

Akuta N, Suzuki F, Suzuki Y, Sezaki H, Hosaka T, Someya T, et al. Favorable efficacy of long-term lamivudine therapy in patients with chronic hepatitis B: an 8-year follow-up study. J Med Virol. 2005;75(4):491-8. [pmid: 15714490].
Alderman EM, Shapiro A, Spigland I, Coupey SM, Bashir M, Fox AS. Are there risk factors for hepatitis B infection in inner-city adolescents that justify prevaccination screening?. J Adolesc Health. 1998;22(5):389-93. [pmid: 9589340].
Andreone P, Cursaro C, Gramenzi A, Zavagliz C, Rezakovic I, Altomare E, et al. A randomized controlled trial of thymosin-alpha1 versus interferon alfa treatment in patients with hepatitis B e antigen antibody--and hepatitis B virus DNA--positive chronic hepatitis B. Hepatology. 1996;24(4):774-7. [pmid: 8855175].
Ascione A, Ascione T, Lanza AG, Utech W, Di Costanzo GG, Macri M. Factors influencing outcome of lamivudine in anti-HBe-positive chronic hepatitis B. HepatoGastroenterology. 2006;53(72):919-23. [pmid: 17153453].
Bosch O, Moraleda G, Castillo I, Carreno V. Treatment of chronic hepatitis B with recombinant interferon alpha versus recombinant interferon alpha plus levamisole. J Hepatol. 1993;19(3):437-41. [pmid: 8151105].
Chang MH, You SL, Chen CJ, Liu CJ, Lee CM, Lin SM, et al. Decreased incidence of hepatocellular carcinoma in hepatitis B Vaccinees: a 20-year follow-up study. J Natl Cancer Inst. 2009;101(19):1348-55. [pmid: 19759364].
Da Silva LC, Pinho JR, Sitnik R, Da Fonseca LE, Carrilho FJ. Efficacy and tolerability of long-term therapy using high lamivudine doses for the treatment of chronic hepatitis B. J Gastroenterol. 2001;36(7):476-85. [pmid: 11480792].
Da Villa G. Successful mass vaccination against hepatitis B virus in a hyperendemic area in Italy. Res Virol. 1993;144(4):255-8. [pmid: 8210705].
Dai CY, Yu ML, Hsieh MY, Lee LP, Hou NJ, Huang JF, et al. Early response to lamivudine therapy in clinically non-cirrhotic chronic hepatitis B patients with decompensation. Liver Int. 2007;27(10):1364-70. [pmid: 17900250].
Del Poggio P, Zaccanelli M, Oggionni M, Colombo S, Jamoletti C, Puhalo V. Low-dose tenofovir is more potent than adefovir and is effective in controlling HBV viremia in chronic HBeAg-negative hepatitis B. World J Gastroenterol. 2007;13(30):4096-9. [pmid: 17696228].
Demirturk N, Usluer G, Ozgunes I, Colak H, Kartal ED, Dincer S. Comparison of different treatment combinations for chronic hepatitis B infection. J Chemother. 2002;14(3):285-9. [pmid: 12120884].
Dienstag JL, Perrillo RP, Schiff ER, Bartholomew M, Vicary C, Rubin M. A preliminary trial of lamivudine for chronic hepatitis B infection. N Engl J Med. 1995;333(25):1657-61. [pmid: 7477217].
Dooley JS, Davis GL, Peters M, Waggoner JG, Goodman Z, Hoofnagle JH. Pilot study of recombinant human alpha-interferon for chronic type B hepatitis. Gastroenterology. 1986;90(1):150-7. [pmid: 3940241].
Eisenberg M, Rosno S, Garcia G, Konrad MW, Gregory PB, Robinson WS, et al. Preliminary trial of recombinant fibroblast interferon in chronic hepatitis B virus infection. Antimicrob Agents Chemother. 1986;29(1):122-6. [pmid: 3524420].
Gonzalez-Mateos F, Garcia-Monzon C, Garcia-Buey L, Garcia-Sanchez A, Pajares JM, Moreno-Otero R. Long-term effect of interferon alpha alone or after prednisone withdrawal in chronic hepatitis B. Interim report and review of the literature. HepatoGastroenterology. 1995;42(6):893-9. [pmid: 8847042].
Hope RL, Weltman M, Dingley J, Fiatarone J, Hope AH, Craig PI, et al. Interferon alfa for chronic active hepatitis B. Long term follow-up of 62 patients: outcomes and predictors of response. Med J Aust. 1995;162(1):8-11. [pmid: 7845310].
Kim HJ, Park DI, Park JH, Cho YK, Sohn CI, Jeon WK, et al. Comparison between clevudine and entecavir treatment for antiviral-naive patients with chronic hepatitis B. Liver Int. 2010;30(6):834-40. [pmid: 20408946].
Krogsgaard K, Marcellin P, Trepo C, Berthelot P, Sanchez-Tapias JM, Bassendine M, et al. Prednisolone withdrawal therapy enhances the effect of human lymphoblastoid interferon in chronic hepatitis B. INTERPRED Trial Group. J Hepatol. 1996;25(6):803-13. [pmid: 9007706].
Kurashige N, Ohkawa K, Hiramatsu N, Yakushijin T, Mochizuki K, Oze T, et al. Lamivudine-to-entecavir switching treatment in type B chronic hepatitis patients without evidence of lamivudine resistance. J Gastroenterol. 2009;44(8):864-70. [pmid: 19475333].
Kurokawa M, Hiramatsu N, Oze T, Yakushijin T, Miyazaki M, Hosui A, et al. Long-term effect of lamivudine treatment on the incidence of hepatocellular carcinoma in patients with hepatitis B virus infection. J Gastroenterol. 2012;47(5):577-85. [pmid: 22231575].
Lai CL, Gane E, Liaw YF, Hsu CW, Thongsawat S, Wang Y, et al. Telbivudine versus lamivudine in patients with chronic hepatitis B. N Engl J Med. 2007;357(25):2576-88. [pmid: 18094378].
Lai CL, Yuen MF, Hui CK, Garrido-Lestache S, Cheng CTK, Lai YP. Comparison of the efficacy of lamivudine and famciclovir in Asian patients with chronic hepatitis B: results of 24 weeks of therapy. J Med Virol. 2002;67(3):334-8. [pmid: 12116023].
Liaw YF, Sheen IS, Lee CM, Akarca US, Papatheodoridis GV, Suet-Hing Wong F, et al. Tenofovir disoproxil fumarate (TDF), emtricitabine/TDF, and entecavir in patients with decompensated chronic hepatitis B liver disease. Hepatology. 2011;53(1):62-72. [pmid: 21254162].
Leung NW, Lai CL, Chang TT, Guan R, Lee CM, Ng KY, et al. Extended lamivudine treatment in patients with chronic hepatitis B enhances hepatitis B e antigen seroconversion rates: results after 3 years of therapy. Hepatology. 2001;33(6):1527-32. [pmid: 11391543].
Liaw YF, Jia JD, Chan HLY, Han KH, Tanwandee T, Chuang WL, et al. Shorter durations and lower doses of peginterferon alfa-2a are associated with inferior hepatitis B e antigen seroconversion rates in hepatitis B virus genotypes B or C. Hepatology. 2011;54(5):1591-9. [pmid: 22045673].
Liaw YF, Leung NW, Chang TT, Guan R, Tai DI, Ng KY, et al. Effects of extended lamivudine therapy in Asian patients with chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. Gastroenterology. 2000;119(1):172-80. [pmid: 10889166].
Lok AS, Novick DM, Karayiannis P, Dunk AA, Sherlock S, Thomas HC. A randomized study of the effects of adenine arabinoside 5'-monophosphate (short or long courses) and lymphoblastoid interferon on hepatitis B virus replication. Hepatology. 1985;5(6):1132-8. [pmid: 2415436].
Ma H, Yang RF, Wei L. Quantitative serum HBsAg and HBeAg are strong predictors of sustained HBeAg seroconversion to pegylated interferon alfa-2b in HBeAg-positive patients. J Gastroenterol Hepatol. 2010;25(9):1498-506. [pmid: 20796146].
Marcellin P, Bonino F, Lau GKK, Farci P, Yurdaydin C, Piratvisuth T, et al. Sustained response of hepatitis B e antigen-negative patients 3 years after treatment with peginterferon alpha-2a. Gastroenterology. 2009;136(7):2169-79.e1-4. [pmid: 19303414].
Mazur W, Krol F, Cianciara J, Nazzal K, Gladysz A, Juszczyk J, et al. A multi-center open study to determine the effect of lamivudine on HBV DNA clearance and to assess the safety of the regimen in patients with chronic hepatitis B infection. Med Sci Monit. 2002;8(4):CR257-62. [pmid: 11951067].
Mellerup MT, Krogsgaard K, Mathurin P, Gluud C, Poynard T. Sequential combination of glucocorticosteroids and alfa interferon versus alfa interferon alone for HBeAg-positive chronic hepatitis B. Cochrane Database Syst Rev. 2002;(2):CD000345. [pmid: 12076393].
Mihm U, Sarrazin C, Herrmann E, Teuber G, von Wagner M, Kronenberger B, et al. Response predictors and results of a long-term treatment with lamivudine in patients with chronic hepatitis B. Z Gastroenterol. 2003;41(3):249-54. [pmid: 12664345].
Minuk GY, German GB, Bernstein C, Benarroch A, Gauthier T, Sekla L. A pilot study of steroid withdrawal followed by oral acyclovir in the treatment of chronic type B hepatitis. Clin Invest Med. 1992;15(6):506-12. [pmid: 1286532].
Montesano R. Hepatitis B immunization and hepatocellular carcinoma: The Gambia Hepatitis Intervention Study. J Med Virol. 2002;67(3):444-6. [pmid: 12116042].
Munoz R, Castellano G, Fernandez I, Alvarez MV, Manzano ML, Marcos MS, et al. A pilot study of beta-interferon for treatment of patients with chronic hepatitis B who failed to respond to alpha-interferon. J Hepatol. 2002;37(5):655-9. [pmid: 12399233].
Musch E, Hogemann B, Gerritzen A, Fischer HP, Wiese M, Kruis W, et al. Phase II clinical trial of combined natural interferon-beta plus recombinant interferon-gamma treatment of chronic hepatitis B. HepatoGastroenterology. 1998;45(24):2282-94. [pmid: 9951911].
Nevens F, Main J, Honkoop P, Tyrrell DL, Barber J, Sullivan MT, et al. Lamivudine therapy for chronic hepatitis B: a six-month randomized dose-ranging study. Gastroenterology. 1997;113(4):1258-63. [pmid: 9322520].
Oliveri F, Santantonio T, Bellati G, Colombatto P, Mels GC, Carriero L, et al. Long term response to therapy of chronic anti-HBe-positive hepatitis B is poor independent of type and schedule of interferon. Am J Gastroenterol. 1999;94(5):1366-72. [pmid: 10235220].
Omata M, Imazeki F, Yokosuka O, Ito Y, Uchiumi K, Mori J, et al. Recombinant leukocyte a interferon treatment in patients with chronic hepatitis B virus infection. Pharmacokinetics, tolerance, and biologic effects. Gastroenterology. 1985;88(4):870-80. [pmid: 3972231].
Pradeep Kumar S, Medhi S, Asim M, Das BC, Gondal R, Kar P. Evaluation of adefovir & lamivudine in chronic hepatitis B: correlation with HBV viral kinetic, hepatic-necro inflammation & fibrosis. Indian J Med Res. 2011;133:50-6. [pmid: 21321419].
Roushan MR, Samie H, Amiri MJS. Efficacy of hepatitis B Vaccine in susceptible spouses of chronic hepatitis B virus infected individuals at the time of marriage. Saudi Med J. 2007;28(4):540-3. [pmid: 17457474].
Saruc M, Yuceyar H, Kucukmetin N, Demir MA, Kandiloglu AR. Combination thymosin-alpha 1 and interferon-alpha 2b in the treatment of anti-HBe-positive chronic hepatitis B in Turkey. HepatoGastroenterology. 2002;49(45):798-802. [pmid: 12063993].
Schiff E, Simsek H, Lee WM, Chao YC, Sette H Jr., Janssen HLA, et al. Efficacy and safety of entecavir in patients with chronic hepatitis B and advanced hepatic fibrosis or cirrhosis. [Erratum appears in Am J Gastroenterol. 2009; 104(2):540]. Am J Gastroenterol. 2008;103(11):2776-83. [pmid: 18721244].
Scullard GH, Pollard RB, Smith JL, Sacks SL, Gregory PB, Robinson WS, et al. Antiviral treatment of chronic hepatitis B virus infection. I. Changes in viral markers with interferon combined with adenine arabinoside. J Infect Dis. 1981;143(6):772-83. [pmid: 6166691].
Shepherd J, Jones J, Takeda A, Davidson P, Price A. Adefovir dipivoxil and pegylated interferon alfa-2a for the treatment of chronic hepatitis B: a systematic review and economic evaluation. Health Technol Assess. 2006;10(28):iii-iv. xi. xiv. 1. 183. [pmid: 16904047].
Smith CI, Weissberg J, Bernhardt L, Gregory PB, Robinson WS, Merigan TC. Acute Dane particle suppression with recombinant leukocyte A interferon in chronic hepatitis B virus infection. J Infect Dis. 1983;148(5):907-13. [pmid: 6631076].
Suh DJ, Um SH, Herrmann E, Kim JH, Lee YS, Lee HJ, et al. Early viral kinetics of telbivudine and entecavir: results of a 12-week randomized exploratory study with patients with HBeAg-positive chronic hepatitis B. Antimicrob Agents Chemother. 2010;54(3):1242-7. [pmid: 20028815].
Sypsa V, Hadjipaschali E, Hatzakis A. Prevalence, risk factors and evaluation of a screening strategy for chronic hepatitis C and B virus infections in healthy company employees. Eur J Epidemiol. 2001;17(8):721-8. [pmid: 12086089].
Villeneuve JP, Condreay LD, Willems B, Pomier-Layrargues G, Fenyves D, Bilodeau M, et al. Lamivudine treatment for decompensated cirrhosis resulting from chronic hepatitis B. Hepatology. 2000;31(1):207-10. [pmid: 10613747].
Wolters LM, van Nunen AB, Niesters HG, de Man RA. Contrasting patterns of response to lamivudine monotherapy in chronic hepatitis B patients. Scand J Gastroenterol Suppl. 2000;(232):74-8. [pmid: 11232497].
Yao GB, Zhu M, Wang YM, Xu DZ, Tan DM, Chen CW, et al. A double-blind, double-dummy, randomized, controlled study of entecavir versus lamivudine for treatment of chronic hepatitis B. Zhonghua Nei Ke Za Zhi. 2006;45(11):891-5. [pmid: 17313873].
Zavaglia C, Bottelli R, Bellati G, Asti L, Mondazzi L, Iamoni G, et al. Treatment of chronic hepatitis B (HBeAg-HBV DNA-positive) with lymphoblastoid alpha interferon with or without corticosteroids: short- and long-term follow-up. Ital J Gastroenterol. 1996;28(6):324-31. [pmid: 8891847].
Zhao H, Si CW, Wei L, Wan MB, Ying YK, Hou JL, et al. A multicenter, randomized, open-label study of the safety and effectiveness of pegylated interferon alpha 2b and interferon alpha 2b in treating HBeAg positive chronic hepatitis B patients. Zhonghua Gan Zang Bing Za Zhi. 2006;14(5):323-6. [pmid: 16732903].
Zheng Y, Zhao L, Wu T, Guo S, Chen Y, Zhou T. Efficacy of consensus interferon in treatment of HbeAg-positive chronic hepatitis B: a multicentre, randomized controlled trial. Virol J. 2009;6:99. [pmid: 19586556].
Zhu M, Xu B, Yao GB. Durability of HBeAg seroconversion in lamivudine treatment of chronic hepatitis B patients. Zhonghua Gan Zang Bing Za Zhi. 2005;13(7):534-6. [pmid: 16042894].
Zollner B, Petersen J, Schafer P, Schroter M, Laufs R, Sterneck M, et al. Subtype-dependent response of hepatitis B virus during the early phase of lamivudine treatment. Clin Infect Dis. 2002;34(9):1273-7. [pmid: 11941556].
Zollner B, Schafer P, Feucht HH, Schroter M, Petersen J, Laufs R. Correlation of hepatitis B virus load with loss of e antigen and emerging drug-resistant variants during lamivudine therapy. J Med Virol. 2001;65(4):659-63. [pmid: 11745928].
Zylberberg H, Jiang J, Pialoux G, Driss F, Carnot F, Dubois F, et al. Alpha-interferon for chronic active hepatitis B in human immunodeficiency virus-infected patients. Gastroenterol Clin Biol. 1996;20(11):968-71. [pmid: 9119186].
Rakela J, Wood JR, Czaja AJ, O'Brien PC, Taswell HF, Bowyer BA, et al. Long-term versus short-term treatment with recombinant interferon alfa-2a in patients with chronic hepatitis B: a prospective, randomized treatment trial. Mayo Clin Proc. 1990;65(10):1330-5. [pmid: 2214880].

### Duplicate Data

Chang TT, Lai CL, Chien RN, Guan R, Lim SG, Lee CM, et al. Four years of lamivudine treatment in Chinese patients with chronic hepatitis B. J Gastroenterol Hepatol. 2004;19(11):1276-82. [pmid: 15482535].
Cooksley H, Chokshi S, Maayan Y, Wedemeyer H, Andreone P, Gilson R, et al. Hepatitis B virus e antigen loss during adefovir dipivoxil therapy is associated with enhanced virus-specific CD4+ T-cell reactivity. Antimicrob Agents Chemother. 2008;52(1):312-20. [pmid: 17984230].
Izzedine H, Hulot JS, Launay-Vacher V, Marcellini P, Hadziyannis SJ, Currie G, et al. Renal safety of adefovir dipivoxil in patients with chronic hepatitis B: two double-blind, randomized, placebo-controlled studies. Kidney Int. 2004;66(3):1153-8. [pmid: 15327411].
Lim SG, Marcellin P, Tassopoulos N, Hadziyannis S, Chang TT, Tong M, et al. Clinical trial: Effects of adefovir dipivoxil therapy in Asian and Caucasian patients with chronic hepatitis B. Aliment Pharmacol Ther. 2007;26(10):1419-28. [pmid: 17983369].
Lok AS, Ma OC, Lau JY. Interferon alfa therapy in patients with chronic hepatitis B virus infection. Effects on hepatitis B virus DNA in the liver. Gastroenterology. 1991;100(3):756-61. [pmid: 1993497].
Lok ASF, Lai CL, Leung N, Yao GB, Cui ZY, Schiff ER, et al. Long-term safety of lamivudine treatment in patients with chronic hepatitis B. Gastroenterology. 2003;125(6):1714-22. [pmid: 14724824].
Perrillo RP, Lai CL, Liaw YF, Dienstag JL, Schiff ER, Schalm SW, et al. Predictors of HBeAg loss after lamivudine treatment for chronic hepatitis B. Hepatology. 2002;36(1):186-94. [pmid: 12085364].
Sung JJY, Tsoi KKF, Wong VWS, Li KCT, Chan HLY. Meta-analysis: Treatment of hepatitis B infection reduces risk of hepatocellular carcinoma. Aliment Pharmacol Ther. 2008;28(9):1067-77. [pmid: 18657133].
Yao GB. Management of hepatitis B in China. J Med Virol. 2000;61(3):392-7. [pmid: 10861652].
Yao GB, Zhu M, Cui ZY, Wang BE, Yao JL, Zeng MD. A 7-year study of lamivudine therapy for hepatitis B virus e antigen-positive chronic hepatitis B patients in China. J Dig Dis. 2009;10(2):131-7. [pmid: 19426396].
Yuen MF, Chow DH, Tsui K, Wong BC, Yuen JC, Wong DK, et al. Liver histology of Asian patients with chronic hepatitis B on prolonged lamivudine therapy. Aliment Pharmacol Ther. 2005;21(7):841-9. [pmid: 15801919].
Yuen MF, Seto WK, Chow DHF, Tsui K, Wong DKH, Ngai VWS, et al. Long-term lamivudine therapy reduces the risk of long-term complications of chronic hepatitis B infection even in patients without advanced disease. Antivir Ther. 2007;12(8):1295-303. [pmid: 18240869].
Zhang QQ, An X, Liu YH, Li SY, Zhong Q, Wang J, et al. Long-term nucleos(t)ide analogues therapy for adults with chronic hepatitis B reduces the risk of long-term complications: a meta-analysis. Virol J. 2011;8:72. [pmid: 21324130].

## Appendix A5 U.S. Preventive Services Task Force Quality Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases.
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Source: U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. July. 2008. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. .

## Appendix A6 List of Reviewers

### Expert Reviewers

Anna S. F. Lok, MD, MBBS, FRCP, Director, Clinical Hepatology, University of Michigan Health System

Bruce Runyon, MD, Director, Hepatology, UCLA Medical Center, Santa Monica; Author of American Association for the Study of Liver Diseases National Practice Guideline

John Ward, MD, Director, Viral Hepatitis Program, National Center of HIV/AIDS, Viral Hepatitis, STD, and TB Prevention, Centers for Disease Control and Prevention

### Federal Reviewers

Sarah Schillie, MD, MPH, MBA, Division of Viral Hepatitis, Centers for Disease Control and Prevention

Rebecca Morgan, MPH, Division of Viral Hepatitis, Centers for Disease Control and Prevention

Linda Kinsinger, MD, MPH, VHA, Chief Consultant of Preventive Medicine, National Center for Health Promotion and Disease Prevention

Jeffrey Murray, MD, MPH, Deputy, Division of Antiviral Products, Federal Drug Administration