# Acknowledgements

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (contract #290-97-0018, task order no. 2) to be used by the U.S. Preventive Services Task Force. Task Force members Janet Allen, PhD, RN, and Steven Teutsch, MD, MPH, served as liaisons. Oregon Health Sciences University Evidence-based Practice Center staff who contributed to this project include Peggy Nygren MA, research associate, and Patty Davies, MA, librarian.