# References

1 Keating NL, Cleary PD, Rossi AS, Zaslavsky AM, Ayanian JZ. Use of hormone replacement therapy by postmenopausal women in the United States. Ann Intern Med. 1999;130:545-553. [pmid: 10189323].
2 Vessey M, Mant D, Smith A, Yeates D. Oral contraceptives and venous thromboembolism: findings in a large prospective study. BMJ Clin Ed. 1986;292.
3 A report from the Boston Collaborative Drug Surveillance Program, Boston University Medical Center. N Engl J Med. 1974;290:15-19. [pmid: 4357161].
4 Petitti DB, Wingerd J, Pellegrin F, Ramcharan S. Risk of vascular disease in women. Smoking, oral contraceptives, noncontraceptive estrogens, and other factors. JAMA. 1979;242:1150-1154. [pmid: 470067].
5 Nachtigall LE, Nachtigall RH, Nachtigall RD, Beckman EM. Estrogen replacement therapy II: a prospective study in the relationship to carcinoma and cardiovascular and metabolic problems. Obstet Gynecol. 1979;54:74-79. [pmid: 221871]. [pmcid: 1545194].
6 Daly E, Vessey MP, Hawkins MM, Carson JL, Gough P, Marsh S. Risk of venous thromboembolism in users of hormone replacement therapy. Lancet. 1996;348:977-980. [pmid: 8855852].
7 Daly E, Vessey MP, Painter R, Hawkins MM. Case-control study of venous thromboembolism risk in users of hormone replacement therapy [letter]. Lancet. 1996;348.
8 Jick H, Derby LE, Myers MW, Vasilakis C, Newton KM. Risk of hospital admission for idiopathic venous thromboembolism among users of postmenopausal oestrogens. Lancet. 1996;348:981-983. [pmid: 8855853].
9 Perez-Gutthann S, Garcia-Rodriguez LA, Castellsague J, Duque Oliart A. Hormone replacement therapy and risk of venous thromboembolism: population based case-control study. BMJ. 1997;314:796-800. [pmid: 9081000]. [pmcid: 2126205].
10 Varas-Lorenzo C, Garcia-Rodriguez LA, Cattaruzzi C, Troncon MG, Agostinis L, Perez-Gutthann S. Hormone replacement therapy and the risk of hospitalization for venous thromboembolism: a population-based study in southern Europe. Am J Epidemiol. 1998;147:387-390. [pmid: 9508106].
11 Grodstein F, Stampfer MJ, Goldhaber SZ, et al. Prospective study of exogenous hormones and risk of pulmonary embolism in women. Lancet. 1996;348:983-987. [pmid: 8855854].
12 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280:605-613. [pmid: 9718051].
13 Hoibraaten E, Abdelnoor M, Sandset PM. Hormone replacement therapy with estradiol and risk of venous thromboembolism--a population-based case-control study. Thromb Haemost. 1999;82:1218-1221. [pmid: 10544901].
14 US. Preventive Services Task Force. Gde to Clinical Preventive Services. 2nd ed. Baltimore: Williams & Wilkins. 1996.
15 The Writing Group for the PEPI Trial. Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women: The postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. [published erratum appears in JAMA. 1995;274(21):1676]. JAMA. 1995;273:199-208. [pmid: 7807658].
16 Herrington DM, Reboussin DM, Brosnihan KB, et al. Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med. 2000;343:522-529. [pmid: 10954759].
17 Devor M, Barrett-Connor E, Renvall M, Feigal D Jr, Ramsdell J. Estrogen replacement therapy and the risk of venous thrombosis. Am J Med. 1992;92:275-282. [pmid: 1546726].
18 Petitti DB, Wingerd J, Pellegrin F, Ramcharan S. Oral contraceptives, smoking, and other factors in relation to risk of venous thromboembolic disease. Am J Epidemiol. 1978;108:480-485. [pmid: 736027].
19 Douketis JD, Ginsberg JS, Holbrook A, Crowther M, Duku EK, Burrows RF. A reevaluation of the risk for venous thromboembolism with the use of oral contraceptives and hormone replacement therapy. Arch Intern Med. 1997;157:1522-1530. [pmid: 9236553].
20 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90:1371-1388. [pmid: 9747868].
21 Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998;352:93-97. [pmid: 9672273].
22 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352:98-101. [pmid: 9672274].
23 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999;281:2189-2197. [pmid: 10376571].
24 Lufkin EG, Whitaker MD, Nickelsen T, et al. Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998;13:1747-1754. [pmid: 9797484].
25 Harris R, Helfand M, Woolf S, et al Current methods of the Third U. S. Preventive Services Task Force: A review of the process Am J Prev Med 2001 20(suppl 3):21 35 11306229
26 Normand SL. Meta-analysis: formulating, evaluating, combining, and reporting. Stat Med. 1999;18:321-359. [pmid: 10070677].
27 Spiegelhalter D, Thomas A, Best N. WinBUGS Version 1. 2 User Manual. Cambridge, England: MRC Biostatistics Unit. 1999.
28 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-634. [pmid: 9310563]. [pmcid: 2127453].
29 Duval S, Tweedie R. A Nonparametric "trim and fill" method of accounting for publication bias in meta-analysis. J Am Stat Assoc. 2000;95:89-98.
30 Sutton A, Duval S, Tweedie R, Abrams K, Jones D. Empirical assessment of effect of publication bias on meta-analysis. BMJ. 2000;320:1574-1577. [pmid: 10845965]. [pmcid: 27401].
31 Grady D, Wenger NK, Herrington D, et al. Postmenopausal hormone therapy increases risk for venous thromboembolic disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2000;132:689-696. [pmid: 10787361].
32 Coronary Drug Project Research Group. The Coronary Drug Project: findings leading to discontinuation of the 2. 5 mg/day estrogen group. JAMA. 1973;226:652-657. [pmid: 4356847].
33 Wenger N. Early risks of hormone therapy in patients with coronary heart disease [letter]. JAMA. 2000;284:41-43. [pmid: 10872009].
34 National Heart Lung and Blood Institute (NHLBI). Statement from Claudia Lenfant, MD, NHLBI Director, on preliminary trends in the Women's Health Initiative (WHI). National Heart, Lung and Blood Institute: Bethesda, Maryland. 2000. [pmcid: 384376].
35 Women's Health Initiative (WHI) Data and Safety Monitoring Board (DSMB). New hormone program information. WHI HRT Update. 2001:1-2.
36 Kearon C, Julian JA, Newman TE, Ginsberg JS. Noninvasive diagnosis of deep venous thrombosis. McMaster Diagnostic Imaging Practice Gdelines Initiative [published erratum appears in Ann Intern Med. 1998;129(5):425]. Ann Intern Med. 1998;128:663-677. [pmid: 9537941].
37 The Prospective Investigation of Pulmonary Embolism Diagnosis (PIOPED) Investigators. Value of the ventilation/perfusion scan in acute pulmonary embolism: Results of the PIOPED. JAMA. 1990;263:2753-2759. [pmid: 2332918].
38 Rosenberg L, Palmer JR, Adams-Campbell LL. Postmenopausal female hormone use and venous thromboembolic disease in black women [letter]. Am J Obstet Gynecol. 1997;177.
39 Scarabin PY, Alhenc-Gelas M, Plu-Bureau G, Taisne P, Agher R, Aiach M. Effects of oral and transdermal estrogen/progesterone regimens on blood coagulation and fibrinolysis in postmenopausal women. A randomized controlled trial. Arterioscler Thromb Vasc Biol. 1997;17:3071-3078. [pmid: 9409295].
40 Ruehlmann DO, Mann GE. Actions of oestrogen on vascular endothelial and smooth-muscle cells. Biochem Soc Trans. 1997;25:40-45. [pmid: 9056840].
41 Koh K, Horne M, Cannon R. Effects of hormone replacement therapy on coagulation, fibrinolysis, and thrombosis in postmenopausal women. Thromb Haemost. 1999;82:626-633. [pmid: 10605760].
42 Whiteman MK, C Y, Flaws JA, Espeland M, Bush TL. Low fibrinogen level: A predisposing factor for venous thromboembolic events with hormone replacement therapy. Am J Hematol. 1999;61:271-273. [pmid: 10440916].
43 The Writing Group for the Estradiol Clotting Factors Study. Effects on haemostasis of hormone replacement therapy with transdermal estradiol and oral sequential medroxyprogesterone acetate: a 1-year, double-blind, placebo-controlled study. Thromb Haemost. 1996;75:476-480. [pmid: 8701411]. [pmcid: 484344].
44 Hoibraaten E, Qvigstad E, Arnesen H, Larsen S, Wickstrom E, Sandset P. Increased risk of recurrent venous thromboembolism during hormone repacement therapy - results of the randomized, double-blind, placebo-controlled estrogen in venous thromboembolism trial (EVTET). Thromb Haemost. 2000;84:961-967. [pmid: 11154141].
45 Glueck CJ, Wang P, Fontaine RN, Tracy T, Sieve-Smith L, Lang JE. Effect of exogenous estrogen on atherothrombotic vascular disease risk related to the presence or absence of the factor V Leiden mutation (resistance to activated protein C). Am J Cardiol. 1999;84:549-554. [pmid: 10482153].
46 Lowe G, Woodward M, Vessey M, Rumley A, Gough P, Daly E. Thrombotic variables and risk of idiopathic venous thromboembolism in women aged 45-64 years. Relationships to hormone replacement therapy. Thromb Haemost. 2000;83:530-535. [pmid: 10780311].