# Discussion

## Conclusions

Our literature review and meta-analysis of 12 eligible studies indicated that postmenopausal HRT is associated with a 2-fold increase in risk of venous thromboembolism in current users (RR, 2.14; CI, 1.64-2.81). Using a baseline risk of 1.3 events per 10,000 woman-years based on a study with 10,000 controls, an additional 1.5 events per 10,000 women each year would be expected.^ 9 ^ A summary of the evidence is described in Table 3. The 2 largest trials of SERMs reported a similar statistically significant increased risk.^20,23^

Table 3. Summary of Evidence

Key Question | Evidence Codes* | Quality of Evidence
Does HRT increase the risk for venous thromboembolism? | I | RCTs: Poor to good. Venous thromboembolism is a secondary outcome, groups randomized for cardiac outcomes, method of outcome assessment not reported.
Does HRT increase the risk for venous thromboembolism? | II-2 | Case-control: Poor to good. Analysis based on small numbers of cases, important confounders such as smoking not considered in some studies.
Does HRT increase the risk for venous thromboembolism? | II-2 | Cohort: Good.

*Study design categories^ 14 ^

I: Randomized, controlled trialsII-1: Controlled trials without randomizationII-2: Cohort or case-control analytic studiesII-3: Multiple time seies, dramatic uncontrolled experimentsIII: Opinions of respected authorities, descriptive epidemiology

The findings of recent studies of HRT and SERMs differ substantially from studies published earlier that showed no association.^3-5^ However, these earlier studies have several methodologic limitations, and two of the studies^4,5^ did not meet our inclusion criteria for the meta-analysis. A case-control study, using data from the Walnut Creek Contraceptive Drug Study, was designed to identify adverse outcomes of chronic oral contraceptive use.^ 4 ^ The study reported 17 idiopathic cases of venous thromboembolism in users of oral contraceptives or those with "other estrogenic use," however, it is not clear if "other estrogenic use" represented postmenopausal HRT. Of the 17 cases, more than half were younger than 45 years old. A randomized controlled trial^ 5 ^ followed an inpatient population of women from a hospital for chronic diseases for 10 years, limiting generalizability to a community-based ambulatory population. While the earliest case-control study included in our meta-analysis did not have significant findings, it did show a trend toward increased events.^ 3 ^

More recently, the Coronary Drug Project (CDP)^ 32 ^ was reanalyzed, and an increased risk (RH, 1.62; 1.62-2.29) was reported.^ 33 ^ This randomized controlled trial of men with known coronary artery disease compared 2 doses of estrogen (2.5 mg/d and 5.0 mg/d) to placebo and was discontinued after an increase was observed in mortality, nonfatal myocardial infarction, and adverse effects.

Also, unpublished, preliminary data from the Women's Health Initiative also indicate an increased risk of venous thromboembolism with hormone replacement.^34,35^ The significance of these findings will be more apparent as the study progresses.

## Limitations of the Literature

Studies included in this review had several important limitations. The diagnosis of DVT or PE is difficult, and the literature addressing this topic is complicated. A recent review^ 36 ^ of noninvasive strategies of DVT diagnosis indicated that venous ultrasound is most accurate. However, multiple variables, such as proximal versus distal, symptomatic versus asymptomatic, and first versus recurrent DVT all affect the accuracy of the test.

The Prospective Investigation of Pulmonary Embolism Diagnosis (PIOPED) study^ 37 ^ reported several findings about the utility of V/Q scans for PE diagnosis. A high probability scan usually indicated PE, but few patients diagnosed with PE had a high probability scan. Using pulmonary angiography for comparison, a high probability scan was 41% sensitive and 97% specific. Combining intermediate or high probability scans, these numbers were 82% and 52%, respectively. Also, intermediate probability scans did not contribute to PE diagnosis. Finally, most of the patients in this study, with and without PE, had abnormal V/Q scans.

In the current studies, race was either not indicated^6-11^ or participants were predominantly white.^12,15,17^ Preliminary findings from the Black Women's Health Study indicate a possible increased risk (OR, 1.4; CI, 1.1-1.6) with postmenopausal HRT in African American women.^ 38 ^

Our method of reviewing abstracts and journal articles could have missed venous thromboembolic events that were not reported or reported in a limited way. Obtaining unpublished data from investigators may have provided more studies for the meta-analysis, but this was beyond the scope of our literature review.

## Future Research

Our review supports an association between HRT and venous thromboembolism, although many questions remain. The pathophysiology is not well understood and reqres further study. It is currently thought the effect of estrogen on the vascular endothelium and on coagulation factors might influence the potential for a thromboembolic event.^39,40^ These hypercoagulable states might also be opposed by estrogen-induced clot lysis properties and an imbalance in these processes, in some women, might result in thromboembolism.^ 41 ^ A follow-up analysis of the PEPI trial observed that patients with venous thromboembolism had lower baseline fibrinogen levels than those without.^ 42 ^ The significance of these findings is unclear.

An Italian study suggests that continuous transdermal estradiol results in better hemostatic balance of clotting factors than cyclic estradiol therapy.^ 43 ^ Some studies in our review indicated that higher doses of estrogen^6,8,9^ and use of progestins^6,9,10^ increase risk. However, the effects of dose (low vs conventional), delivery (transdermal vs oral), and adding progestins have not been extensively studied. Additional research is necessary to determine the optimal HRT regimen.

Identifying individuals at highest risk needs further investigation. HERS reported increased risk in patients with hip or lower extremity fracture, cancer, hospitalization, or surgery.^ 31 ^ Other expected risk factors (hypertension, smoking, BMI) were not predictive. Later onset of menopause (above age 52 years) was also associated with increased risk. The use of statin medications and aspirin was protective. However, it is not clear if all of these findings can be extrapolated to women without coronary artery disease. The Estrogen in Venous Thromboembolism Trial (EVTET) reported that women with a prior history of venous thromboembolism while taking hormone replacement are at increased risk for a recurrent event.^ 44 ^ Women with the Factor V Leiden mutation who use HRT are also at increased risk for atherothrombolic^ 45 ^ and venous thromboembolic events.^ 46 ^ Further study is needed to determine the utility of screening for coagulopathies prior to starting hormone replacement.