# Results

## Hormone Replacement Therapy Studies

The 12 studies included in the meta-analysis are listed in Table 1. One of the 3 randomized controlled trials^ 12 ^ reported an increased risk of venous thromboembolism with HRT, while the other studies^15,16^ did not. Six of the 8 case-control studies observed an association.^6-10,13^ The cohort study reported an increased risk of pulmonary embolism in users of HRT.^ 11 ^ Characteristics of these studies are described in the following sections.

Table 1. Studies of Hormone Replacement Therapy Included in Meta-analysis

Study | Number of Subjects (N) | Exposed Cases (N) | Relative Risk (95% CI) | Event Rate Estrogen Users* | Number Needed to Harm† | Quality Rating
Randomized Controlled Trials | Treatment/Placebo
PEPI, 1995^ 15 ^ | 701/174 | 10 | 5.10 (0.30-86.66)‡ | 47.6 | 210 | Fair
Hulley et al., (HERS) 1998^ 12 ^ | 1,380/1,383 | 34 | 2.89 (1.50-5.58) | 12.2 | 256 | Good
Herrington et al., (ERA) 2000^ 16 ^ | 100/104 | 7 | 3.70 (0.45 - 30.44)‡ | 114.4 | 123 | Fair
Case-control Studies | Cases/Controls
Devor et al., 1992^ 17 ^ | 357/236 | 6 | 0.79 (0.30-2.08) | Not Reported | Not Reported | Poor
Daly et al., 1996^ 6 ^ | 103/178 | 44 | 3.5 (1.8-7.0) | 2.7 | 5,882 | Fair
Daly et al., 1996^ 7 ^ | 18/168 | 4 | 2.3 (0.6-8.1) | Not Reported | Not Reported | Poor
Jick et al., 1996^ 8 ^ | 42/168 | 21 | 3.6 (1.6-7.8) | 3.2 | 4,347 | Good
Perez Gutthann et al., 1997^ 9 ^ | 292/10,000 | 37 | 2.1 (1.4-3.2) | 2.7 | 7,142 | Good
Varas-Lorenzo et al., 1998^ 10 ^ | 171/10,000 | 6 | 2.3 (1.0-5.3) | 2.9 | 3,448 | Good
Høibraaten et al., 1999^ 13 ^ | 176/352 | 50 | 1.22 (0.76-1.96) | Not Reported | Not Reported | Fair
Boston Collaborative, 1974^ 3 ^ | 152/774 | 3 | 2.26 (0.61-8.41)‡ | Not Reported | Not Reported | Poor
Cohort Studies | Total Subjects
Grodstein et al., 1996^ 11 ^ | 112,593 | 41 | 2.1 (1.2-3.8) | 2.0§ | 25,000§ | Good

* calculated per 10,000 exposed women in one year

† women needed to treat for one year to cause one additional event

‡ calculated

§ current users

Note: ERA indicates Estrogen Replacement and Atherosclerosis; HERS, Heart and Estrogen/progestin Replacement Study; PEPI, Postmenopausal Estrogen/Progestin Interventions

### Randomized Controlled Trials

None of the 3 randomized controlled trials^12,15,16^ identified by our search were designed to study venous thromboembolism as a primary outcome (Appendix 4, Evidence Table 1). The Heart and Estrogen/progestin Replacement Study (HERS)^ 12 ^ was designed to determine if daily HRT reduces the risk of coronary heart disease (CHD) events in postmenopausal women with pre-existing coronary artery disease. The primary outcome was non-fatal myocardial infarction or CHD death. This 4-year study randomized 2,763 women with a mean age of 66.7 years. Daily use of conjugated eqne estrogen, 0.625 mg, with medroxyprogesterone acetate, 2.5 mg, (Prempro) was compared to placebo. DVT and PE were both secondary outcomes. DVT diagnosis was by venography, impedance plethysmography, or ultrasound. Nuclear lung scan or pulmonary angiography were required for PE diagnosis. There were a total of 34 out of 1,380 (2.5%) thrombotic events in the treatment group and 13 out of 1,383 (0.9%) in the placebo group. Relative hazards were reported as 2.89 (95% CI, 1.50-5.58) for venous thromboembolism, 3.18 (CI, 1.43-7.04) for DVT, and 2.79 (CI, 0.89-8.75) for PE. A second publication from HERS reported idiopathic (relative hazard, 3.1; CI, 0.8-11.3) and non-idiopathic (relative hazard, 2.5; CI, 1.2-5.3) events separately.^ 31 ^ Risk was highest in the first 2 years of estrogen use.

The PEPI trial^ 15 ^ enrolled 875 healthy postmenopausal women, mean age 56.1 years, into one of 5 intervention groups and followed them for 3 years. The interventions included conjugated eqne estrogen, 0.625 mg daily, alone or with a progestin in various forms and dosages compared to placebo. Primary outcomes were cardiovascular disease risk factors, including systolic blood pressure, high-density lipoprotein (HDL) cholesterol, serum insulin, and fibrinogen. Thromboembolic events were reported as adverse experiences during the follow-up phase and their method of measurement was not described. The definition of thrombotic events included DVT, PE, and superficial phlebitis. There were 10 events in the treatment group: 2 with DVT, 2 with PE, and 6 with superficial phlebitis. The placebo group had no reported events, and the difference between the groups was not statistically significant (P=0.42).

The Estrogen Replacement and Atherosclerosis (ERA)^ 16 ^ trial randomized 309 women with angiographic-proven coronary heart disease to estrogen, estrogen and progestin, or placebo, and performed follow-up coronary angiography after approximately 3 years to assess disease progression. A total of 8 venous thromboembolic events were reported: 5 in the estrogen group, 2 in the estrogen/progestin group, and 1 in the placebo group. There was no significant difference between the groups (P=0.16).

The quality ratings using USPSTF criteria were good for HERS and fair for the PEPI and ERA trials. While HERS reported venous thromboembolism as a secondary outcome and described how the diagnosis was made, both the PEPI and ERA trials reported it as an adverse experience and did not describe how it was diagnosed. There were other differences, unrelated to quality ratings, between the trials. The HERS and ERA trials enrolled older, postmenopausal women with documented coronary artery disease (mean age 66.7 years), while PEPI enrolled younger, healthy postmenopausal women (mean age 56.1 years). HERS randomized more than 3 times as many participants as PEPI (2,763 vs 875) and nearly 9 times as many as the ERA trial (2,763 vs 309), allowing for greater power to detect events. The PEPI trial included superficial phlebitis and had only 4 DVT and PE cases. The HERS trial reported an increased risk similar to the observational studies.

### Case-Control Studies

Six of the 8 studies (Appendix 4, Evidence Table 2) reported an increased risk of venous thromboembolism with estrogen use and 3 of them had results that were statistically significant.^6-10,13^ Five studies reported an increased risk in the first year (Figure 3). Two of the 8 case-control studies did not report an increased risk.^3,17^ One of these studies did not use multivariable analysis to control for potential confounders.^ 17 ^

Figure 3. Risk for Venous Thromboembolism by Year of HRT Use

Four studies used hospital-based controls^3,6,7,17^ and 4 studies used population-based controls.^8-10,13^ Women ranged in age from 45 to 79 years. Hormonal preparations varied among the studies. Five studies used various doses of conjugated estrogen,^3,6,8,9,17^ one used transdermal estrogen,^ 10 ^ a Scandinavian study included only estradiol formulations,^ 13 ^ and the other did not report estrogen type.^ 7 ^ The use of a progestin in conjunction with estrogen was not specified in 3 of the studies,^3,7,17^ and dosage and type of progestin use in the remaining studies were not reported.^6,8-10,13^

Exposure history and its ascertainment also varied among studies. HRT usage was described as current, past, never, ever, or nonuser, with variable definitions across the studies. For example, 2 case-control studies^13,17^ defined current use as HRT use at the time of hospital admission, while another study^ 6 ^ defined it as HRT use within the month prior to hospital admission. Still others^8-10^ considered HRT use within the previous 6 months as current use. The methods of determining exposure included interview,^6,7^ chart review,^ 17 ^ chart review and questionnaire,^ 13 ^ and review of various pharmacy databases.^8-10^

The method of outcome assessment also varied among studies. The most rigorous criteria reqred a positive venogram, ultrasound, or doppler for DVT diagnosis and a positive ventilation/perfusion (V/Q) scan for PE.^ 8 ^ In addition, documentation of heparin and oral anticoagulation therapy was required. Another study^ 6 ^ classified cases into categories (definite, probable, possible) based on evidence of venous thromboembolism. A "definite" classification required a positive V/Q scan, pulmonary angiogram, venography, duplex scanning, or radioisotope studies. The "probable" and "possible" classification required only certain signs, symptoms, or less invasive diagnostic procedures (electrocardiogram, chest radiograph, arterial blood gas). Despite this stratification, all cases from these 3 categories were included in the analysis. Another study^ 10 ^ required that cases present with typical signs and symptoms and have a documented positive diagnostic procedure (V/Q scan, pulmonary angiogram, venogram, ultrasound) or necropsy, or have received treatment with anticoagulation for more than 2 months after hospital discharge.

Other studies were less rigorous and either did not indicate the method of outcome measurement,^ 7 ^ used a random sample to validate 10% of the cases,^ 9 ^ or simply stated that all cases had at least one diagnostic test (impedance plethysmography, fibrinogen scans, doppler ultrasound, venogram, V/Q scan, or pulmonary angiogram) in addition to a clinical exam.^ 17 ^ The most recent study^ 13 ^ reported the various diagnostic tests performed (venography, ultrasound, V/Q scan, pulmonary angiography, autopsy, clinical diagnosis) on the cases, though no criteria for study inclusion were cited.

The most common confounders controlled for in these studies were body mass index (BMI)^6,7-10,13^ and history of varicose veins.^6,8-10^ Smoking was controlled for in only 3 studies.^8,9,13^

Some studies reported the effects of dose and regimen, although the numbers of study participants were small. Three studies reported a higher risk for increased doses of estrogen (>0.625 mg conjugated) compared to lower doses.^6,8,9^ A higher risk (OR, 2.2-5.3) for estrogen combined with progestin compared with estrogen alone was reported by 3 studies.^6,9,10^ A comparison of oral (OR, 4.6; CI, 2.1-10.1) and transdermal (OR, 2.0; CI, 0.5-7.6) estrogen was reported by only one study.^ 6 ^

A study conducted in the United Kingdom^ 6 ^ identified 103 women hospitalized with first-time venous thromboembolism and compared them to 178 controls admitted for diagnoses unrelated to HRT. Exclusion criteria included history of previous venous thromboembolism, stroke, myocardial infarction, cancer, and use of anticoagulants or oral contraceptives in the month preceding hospital admission. Patients reporting surgery, pregnancy, trauma, or prolonged bed rest within the prior 6 weeks were also excluded. DVT and PE diagnoses were confirmed by diagnostic maneuvers (V/Q scan, pulmonary angiogram, venography, duplex scanning or radioisotope studies) or signs, symptoms, and less invasive diagnostic maneuvers (electrocardiogram, chest radiograph, arterial blood gas). Hormone use any time in the month prior to hospital admission was categorized as current use. Nonusers were defined as past or never users of HRT. BMI, presence of varicose veins, and socioeconomic status were all controlled for. There were 44 exposed cases, resulting in an odds ratio of 3.5 (CI, 1.8-7.0).

The same author reported similar findings in a study^ 7 ^ published in a letter. This nested case-control study used women previously recrted for a contraceptive study. Cases (n=18) and controls (n=161) were 45 to 64 years and were subject to the same inclusion and exclusion criteria as for the prior study. The hormone dosage and duration were not specified. When the same confounders were controlled for, an increased risk for current users compared to nonusers was reported (OR, 2.3; CI, 0.6-8.1).

A study^ 9 ^ using the General Practice Research Database (n=347,253) in the United Kingdom also included hospitalized patients with first-time venous thromboembolism (n=292). In this study, cases were identified by admission diagnoses. The randomly sampled controls (n=10,000) from this study cohort were not hospitalized. Patients with history of venous thromboembolism, coagulopathy, neoplasm, ischemic heart disease, heart failure, vasculitis, and alcohol-related diagnoses were excluded. All study participants were 50 to 79 years old. Use of HRT was determined using the British National Formulary. Participants were placed into one of 3 categories of HRT usage: current (HRT usage any time within past 6 months), nonuse (no HRT prescription recorded in the formulary), and past use (HRT use greater than 6 months ago). Cases were verified using a 10% random sample of venous thromboembolism admission diagnoses by chart review of discharge diagnosis, clinical symptoms, and diagnostic procedures (not further described). All but one DVT case was confirmed. Of the 292 cases, 81% (n=236) had medical record codes for anticoagulation therapy. The adjusted odds ratio of 2.1 (CI, 1.4-3.2) was based on 37 exposed cases. Confounders controlled for included BMI, history of varicose veins or superficial phlebitis, age, smoking, oophorectomy status, and year of enrollment.

An Italian study^ 10 ^ with 6 estrogen users among 171 exposed cases enrolled a similar number (n=10,000) of controls and had similar definitions for HRT use as the above United Kingdom study.^ 9 ^ It also used pharmacy records to determine exposure. However, in this study, 79% of the participants used transdermal estrogen. Despite this difference, this study reported a similar odds ratio of 2.3 (CI, 1.0-5.3).

A study using data from Group Health Cooperative in Seattle^ 8 ^ reported similar findings (OR, 3.6; CI, 1.6-7.8). This study enrolled only 42 cases and 168 controls. Findings for DVT (OR, 4.0; CI, 1.6-9.7) and PE (OR, 2.5; CI, 0.5-12.2) were also reported separately.

The most recent of the case-control studies^ 13 ^ reported a crude odds ratio of 3.54 (CI, 1.54-8.2) for less than one year of HRT use. There was no risk increase with HRT use longer than one year (OR, 0.66; CI, 0.39-1.10). Of the 176 cases, there were 19 with less than one year of HRT exposure and 26 with more than one year of HRT exposure. Among all current HRT users, the adjusted risk was 1.22 (CI, 0.76-1.94). This study, based in Scandinavia,^ 13 ^ differed from the earlier case-control studies. Only estradiol, in various formulations, was used by the cases and controls (n=352) and doses were not reported. The single exclusion criterion was a history of cancer; consequently, 52% (n=92) of the cases had predisposing factors for venous thromboembolism, and 48% (n=84) were idiopathic. Also, it was the only study to use a questionnaire to obtain exposure history.

One of the 8 case-control studies^ 17 ^ did not report an increased risk (OR, 0.79; CI, 0.30-2.08). This study compared 121 cases of venous thromboembolism identified by hospital discharge diagnosis to 236 age-matched controls. Participants were identified as current users or nonusers, and only 6 cases were exposed to HRT. This study did not use multivariable analysis to control for potential confounders. In addition, there was a significant difference in length of stay between cases and controls in the hospitalized patients enrolled (19.5 days vs 9.2 days). This study also did not report the dosage and duration of hormone use.

The case-control studies had variable quality score ratings (3 good, 3 fair, 2 poor). Some were compromised by small numbers of cases and failure to control for important confounders. For example, 2 studies had 4 and 6 exposed cases, and did not control for smoking.^6,10^ Despite higher numbers of exposed cases, the Scandinavian study^ 13 ^ did not report estradiol doses or method of outcome measurement. In most studies, HRT use (type, dose, duration) and method of determining exposure were inadequately or inconsistently measured. Two studies used pharmacy records to determine HRT exposure.^8,9^ Patient interview is subject to potential recall bias, and pharmacy databases indicate active prescriptions but do not confirm medication compliance. The discrepancy in definition of hormone use is potentially significant because some of the studies indicate increased risk with shorter duration of HRT use. One study was not peer-reviewed,^ 7 ^ and one had significant differences between the cases and controls.^ 17 ^

### Cohort Study

The only cohort study identified from our search^ 11 ^ used 16 years of data from the Nurse's Health Study (Appendix 4, Evidence Table 3). This study reported primary PE only. PE was determined by questionnaire and confirmed by a high probability V/Q scan, positive pulmonary angiogram, or necropsy. HRT use was categorized as current, past, or never, though none of these usage categories was further defined. Reported dosages of estrogen were 0.3 mg, 0.625mg, and 1.25 mg, and use of progestins was not reported. Confounders controlled for in the analysis included age, BMI, hypertension, diabetes, smoking, oral contraceptive use, parity, and elevated cholesterol. There were 22 PEs in the current-use group, resulting in a relative risk of 2.1 (CI, 1.2-3.8), and 19 PEs in the past-use group, resulting in a relative risk of 1.3 (CI, 0.7-2.4). No trends were observed for the various estrogen dosages. In terms of duration, current users of 5 years or more had a relative risk of 1.9 (CI, 0.9-4.0), and those with fewer than 5 years of use had a relative risk of 2.6 (CI, 1.2-5.2) for PE. These figures were based on 10 and 12 cases, respectively. This study had a good quality rating.

## Meta-Analysis of HRT Studies

The 12 HRT studies were included in a meta-analysis. Relative risks and 95% confidence intervals for venous thromboembolism outcomes are indicated in Figure 4. The test of heterogeneity indicated that the studies were not heterogeneous (P>0.10). Combining the 12 studies, the overall relative risk for venous thromboembolism in postmenopausal women using HRT from the fixed-effects model was 2.08 (CI, 1.68-2.54). The results were similar with a random-effects model (RR, 2.14; CI 1.64-2.81). Combining the 8 case-control studies^3,6-10,13,17^ the RR was 1.97 (CI, 1.54-2.47) for the fixed-effects model and 2.05 (CI, 1.40-2.95) for the random-effects model. For the 3 randomized controlled trials,^12,15,16^ the RR estimate was highly variable because there were no events in the placebo group of the PEPI trial. From the fixed-effects model the mean RR was 3.15 (CI, 1.55-5.69), and from the random-effects model the median RR was 3.08 (CI, 0.21-45.14). Six studies that reported risk according to duration of use found the highest risks in the first 1 to 2 years (combined relative risk for first year was 3.49; CI, 2.33-5.59).^6,8-10,12,13^

Figure 4. Meta-analysis of Estrogen Studies

## Studies of Selective Estrogen Receptor Modulators (SERMs)

Five randomized controlled trials^20-24^ of raloxifene and tamoxifen were identified and reviewed (Table 2 and Appendix 4, Evidence Table 4). The quality of the studies varied (2 fair, 3 poor). The 3 studies rated as poor^21,22,24^ did not describe the method of diagnosis. One of them had high dropout rates,^ 21 ^ one had important loss to follow-up,^ 22 ^ and one was underpowered to detect outcomes.^ 24 ^ The larger trials^20,23^ were rated as fair.

Table 2. Trials of Selective Estrogen Receptor Modulators Reporting Thrombotic Events

Study | Subjects (N) | Treatment Events (N) | Placebo Events (N) | Relative Risk (95% CI) | Number Needed to Harm† | Quality Rating
Raloxifene
Lufkin et al., 1998^ 24 ^ | 143 | 0 | 0 | Undefined | Undefined | Poor
Cummings et al., 1999^ 23 ^ (MORE) | 7,705 | 49 | 8 | VTE 3.1 (1.5-6.2) | 155 | Fair
Tamoxifen
Fisher et al., 1998^ 20 ^ (BCPT) | 13,388 | 53 | 28 | VTE 1.91 (1.21-3.02)* DVT 1.60 (0.91-2.86) PE 3.01 (1.15-9.27) | 266 | Fair
Powles et al., 1998^ 22 ^ | 2,471 | 7 | 4 | VTE 1.75 (0.51-5.98)† | 419 | Poor
Veronesi et al., 1998^ 21 ^ | 5,408 | 7 | 4 | VTE 1.76 (0.51-6.01)† | 896 | Poor

* women-years/1 VTE

† calculated

Note: BCPT indicates Breast Cancer Prevention Trial; DVT, Deep Vein Thrombosis; MORE, Multiple Outcomes of Raloxifene Evaluation; PE, Pulmonary Embolism; VTE, Venous Thromboembolism.

The largest study of raloxifene, the Multiple Outcomes of Raloxifene Evaluation (MORE) study,^ 23 ^ demonstrated a 3-fold increase in the risk of venous thromboembolism with daily use of raloxifene. This 3-year trial randomized 7,705 postmenopausal, osteoporotic women (mean age 66.5 years) into one of 3 groups: placebo, 60 mg/d of raloxifene, and 120 mg/d of raloxifene. The primary outcome was newly diagnosed breast cancer, with venous thromboembolism reported as an adverse event rather than a secondary outcome. Identification of thrombotic event was through chart review and was not restricted to idiopathic events. There were a total of 49 events in the raloxifene groups and 8 in the placebo group, resulting in a relative risk of 3.1 (CI, 1.5-6.2). There was no significant difference in the rate of events between the two raloxifene groups. These findings are consistent with studies of HRT. They differ with an earlier, but much smaller, randomized trial of one-year duration^ 24 ^ comparing raloxifene (60 mg and 120 mg) with placebo. The earlier study reported no thromboembolic events in the 143 postmenopausal participants (mean age 68.4 years).

Three randomized controlled trials^20-22^ of tamoxifen for breast cancer prevention have variable findings. All of the studies compared 20 mg of daily tamoxifen to placebo and excluded women with prior history of venous thromboembolism. The largest of the 3 studies, the Breast Cancer Prevention Trial (BCPT),^ 20 ^ randomized 13,000 women. Sixty-seven percent of participants were 40 to 59 years, 24 percent were 60 to 69 years, 6 percent were 70 or older, and the remainder were 35 to 39 years. Mean follow-up time was 4 years. Women in the tamoxifen group had a 3-fold risk of PE (n=18) compared to those in the placebo group (n=6) (RR, 3.01; CI, 1.15-9.27). This risk was more pronounced in women age 50 years or older (RR, 3.19; CI, 1.12-11.15) compared to participants 49 years or younger (RR, 2.0; CI, 0.11-119.62). DVT risk was also increased, though not significantly (RR, 1.60; CI, 0.91-2.86).

A trial conducted in Italy^ 21 ^ randomized 5,400 women and followed them for a median length of 3.8 years. Study participants ranged in age from 35 to 70 years, with 76% between 45 and 59 years. The difference in frequency of vascular events between the tamoxifen group (n=38) and placebo groups (n=18) was significant (P=0.0053). Of 64 events, only 11 were DVT or PE; the remaining events were either superficial phlebitis or other thromboses.

A third trial, conducted in the United Kingdom,^ 22 ^ enrolled nearly 2,500 women (ages 30 to 70 years), who were randomly assigned to tamoxifen or placebo groups with median follow-up of 5.8 years. No significant differences in events were observed between the placebo (n=4) and treatment groups (n=7).

There may be several reasons for the differences in risk among the 3 tamoxifen trials. The British^ 22 ^ and Italian^ 21 ^ studies allowed participants to continue HRT if they were already taking it or to start HRT therapy if indicated. The BCPT^ 20 ^ did not allow HRT use within 3 months of randomization. Another difference was the age of study participants. Sixty-one percent were younger than 50 years old in the British trial^ 22 ^ compared with 40% and 38% for the BCPT^ 20 ^ and Italian^ 21 ^ trial, respectively. There were 3 fatal PEs in the BCPT, reportedly associated with comorbid conditions, but it is unclear if these deaths were actually from PE or the comorbidities. The Italian trial^ 21 ^ had a proportion of women under age 50 similar to the BCPT and observed more vascular events in the tamoxifen group than in the placebo group. However, the majority of these events were superficial phlebitis and not DVT.