# Methods

## Literature Search Strategy

We searched MEDLINE (1966 to December 2000) and HealthSTAR (1975 to December 2000) databases. Additional articles were obtained by reviewing reference lists of pertinent studies and reviews. Multiple search terms were used because venous thromboembolism is usually reported as a secondary or adverse outcome in studies with unrelated primary outcomes. Search terms included hormone replacement therapy, estrogen replacement, thromboembolism, thrombophlebitis, pulmonary embolism, blood clot, thrombosis, blood coagulation disorders, hemostasis, hypercoagulation, fibrinogen, fibrinolysis, anticoagulants, thrombolytic therapy, and randomized controlled trials (Appendix 1a-c).

To identify randomized controlled trials (RCTs), we performed 3 separate searches of the Cochrane Controlled Trials Register using estrogen replacement therapy, hormone replacement, and venous thromboembolism as search terms in various combinations. Only one study,^ 12 ^ previously identified in the MEDLINE search, was appropriate for inclusion. We performed additional MEDLINE searches (1991 to December 2000) to identify randomized controlled trials of tamoxifen and raloxifene in women without breast cancer. Using all 3 databases, (MEDLINE, HealthSTAR, and Cochrane) a total of 7 searches for literature addressing HRT, SERMs, and venous thromboembolism were performed.

## Inclusion/Exclusion Criteria

The studies included in this review enrolled postmenopausal women, and included deep venous thrombosis (DVT), pulmonary embolism (PE), or both as either a primary or secondary outcome or as a reportable adverse event related to HRT or SERM use. When data were available, we reported effects of dose, duration, and progestin use. Only articles with English-language abstracts were considered. We excluded studies where the population was selected based on prior thrombotic events or presence of conditions that are associated with higher risk of thrombosis, such as malignancies.

## Size of Literature Reviewed

We identified 3,363 abstracts from our search of postmenopausal HRT and venous thromboembolism; most did not specifically address this topic and were excluded from full-text review (Appendix 2). Twelve abstracts met inclusion criteria and contained primary data (3 randomized controlled trials,^12,15,16^ 8 case-control studies,^3,6-10,13,17^ and one cohort study^ 11 ^). Three other studies^4,5,18^ identified from a review article^ 19 ^ did not meet inclusion criteria. We found 3 trials from 475 abstracts of tamoxifen^20-22^ and 2 trials from 62 abstracts of raloxifene^23,24^ that reported venous thromboembolic events.

## Data Extraction and Synthesis

From each included study, we abstracted the number of participants, treatment (in randomized controlled trials) or definition and method of determining exposure (in case-control or cohort studies), rates of thromboembolic events, confounders controlled for, methods of outcome measurement, and study duration. Studies varied in their definition of exposure, method of determining exposure, confounders controlled for, and method of diagnosis. Two reviewers independently rated each study's quality using criteria developed by the USPSTF^ 25 ^ (Appendix 3) and had 76% agreement. When reviewers disagreed, a final score was reached through consensus. Abstracted data and quality assessments were entered into evidence tables (Appendix 4).

We performed a meta-analysis of the 12 HRT studies meeting inclusion criteria. Two studies^11,12^ reported hazard ratios from Cox proportional hazards models. A hazard ratio is the ratio of the instantaneous probability of an event in the treatment group compared to that of the control group, and can be thought of as the relative risk. One study^ 15 ^ provided the raw data to calculate the unadjusted relative risk. The remaining studies^6-10,13,17^ reported odds ratios from logistic regression models. Since venous thromboembolism is a fairly rare event, the odds ratio is a good estimate for the relative risk. For uniformity, therefore, we indicated the results from all studies as relative risks (RR).

Under the modeling assumptions made by each study, the logarithm of the relative risk (logRR) had a normal distribution. Standard errors for logRR were calculated from the 95% confidence intervals (CIs) given in the studies or, in the case of the Postmenopausal Estrogen/Progestin Interventions (PEPI) trial,^ 15 ^ from the raw data. The logRR and their standard errors provided the data points for the meta-analysis.

We tested both fixed-effects and random-effects models. A fixed-effects model is fit on the data and assumes only one source of variability (the variability within studies). It also assumes that the patient populations across studies are sufficiently similar and that the results are stable to pool together. A random-effects model assumes a second source of variability among studies. Variation among studies implies that each study potentially estimates different effects sizes. Random-effects models are more conservative in the sense that they allow for more variability in treatment effects.^ 26 ^

We used the Bayesian data analysis framework for the meta-analysis and WinBUGS software to analyze the data.^ 27 ^ Because of the differences in study design between the 12 studies, a meta-analysis was performed for each study type, excluding the single cohort study.

We evaluated studies for selection bias using funnel plots^ 28 ^ and investigated the sensitivity of the analysis to possible missing studies due to publication bias by "trim and fill."^29,30^ Results were unaffected.