# Introduction

In this systematic evidence review (SER), we evaluate data on the relationship between the use of postmenopausal hormone replacement therapy (HRT) and selective estrogen receptor modulators (SERMs) and the risk for venous thromboembolism. We present results of a review of the literature and a meta-analysis of studies reporting data on postmenopausal HRT and venous trhomboembolism. This report is part of a larger project on the risks and benefits of HRT prepared for the U.S. Preventive Services Task Force (USPSTF) to assist them in making recommendations.

## Burden of Suffering

The emerging emphasis on women's health, coupled with an aging population, makes it increasingly important for primary care physicians to be familiar with the risks and benefits of postmenopausal HRT. Although postmenopausal HRT is widely used,^ 1 ^ it poses important health risks. One suspected risk is an increase in venous thromboembolic events. Initially, this relationship was based on studies of oral contraceptives^ 2 ^ and was not supported by studies of HRT.^3-5^ Findings from more recent studies, however, indicate an increase in risk.^6-13^

## Prior Recommendations

Because the literature addressing this issue was limited, previous USPSTF (1996) reported that there was no conclusive evidence to support an association between postmenopausal HRT and thrombosis.^ 14 ^

## Analytic Frameworks and Key Questions

The analytic frameworks in Figures 1 and 2 show the target populations, interventions, and health outcome measures we examined for the overall question of the benefits and risks of postmenopausal HRT. Arrow 3 in Figure 2 corresponds to issues of HRT and venous thromboembolism specifically covered in this report. One key question, "Does HRT increase the risk for venous thromboembolism?" gded our literature review.

We were concerned with HRT as chemoprevention, and therefore focused on the use of either estrogen alone or estrogen combined with progestins in healthy, postmenopausal women. The SERM literature we reviewed was restricted to raloxifene and tamoxifen use in healthy postmenopausal women.

Figure 1. Benefits of Hormone Replacement Therapy: Analytic Framework 1 Note: DVT indicates Deep-vein thrombosis; PE, pulmonary embolus; SERMs, Selective estrogen receptor modulators

Figure 2. Adverse Effects of Hormone Replacement Therapy: Analytic Framework 2 Note: SERMs indicates Selective estrogen receptor modulators