# Appendix 4

Evidence Table 1. HRT and Venous Thromboembolism--Randomized Controlled TrialsAppendix 4

Author, Year | Setting/Population | Eligibility | Number Considered | Exclusions* | Number Randomized | Treatment (n) Placebo(n) | Mean Age | Hormone Type/dosage(s) | Placebo | Compliance Rate/Method | Secondary Outcome Measured | Method of Secondary Outcome Measurement | Study Duration | Follow-up Rate | Relative Hazard (95% CI) | Significance | Quality of Studies
Hulley (HERS), 1998^ 12 ^ | Outpatient and community; 20 U.S. sites; primary outcome nonfatal myocardial infarction or coronary artery disease death. | Post menopausal, < 80 yrs, coronary artery disease, intact uterus. | 68,561 | Cardiac event within 6 mos of randomization; use of HRT within 3 mos of initial visit; history of VTE; history of breast or endometrial cancer. | 2,763 | 1,380/1,383 | 67 Range 44-79 yrs. | CEE 0.625 mg/MPA 2.5 mg | Identical placebo | 70% at 3 yrs; pill count | VTE, DVT, PE | DVT: venography, plethysmography, ultrasound PE: nuclear lung scan, pulmonary angiography | 4.1 yrs | 100% | VTE 2.89 (1.50-5.58) DVT 3.18 (1.43-7.04) PE 2.79 (0.89-8.75) | P<.05 P<.05 P>.05 | Good: VTE a secondary outcome;groups randomized for cardiac outcomes; included non-idiopathic VTE as outcome; not all important confounders considered.
PEPI, 1995^ 15 ^ | Outpatient; 7 U.S. academic centers; primary outcomes: high density lipoproteins, systolic blood pressure, insulin, fibrinogen. | Post menopausal, 45-64 yrs, with or without a uterus. | Not stated | Myocardial infarction within 6 mos; congestive heart failure, cerebrovascular accident, transient ischemic attach, prior breast or endometrial cancer; use of HRT within 3 mos. | 875 | 701/174 | 56.1 Range 45-64 yrs. | CEE 0.625 mg; CEE 0.625 mg +cyclic MPA 10 mg; CEE 0.625 mg +continuous MPA 2.5 mg; CEE 0.625 mg+cyclic MP 200 mg | Identical placebo | >80% at 3 yrs; pill count | DVT and PE not specified outcomes | Not stated | 3 yrs | 97% | not reported | P=0.42 | Poor: VTE reported as "adverse" experience. DVT (n=2), PE (n=2), and superficial phlebitis (n=6).
Herrington, et al (ERA), 2000^ 16 ^ | Outpatient; 6 clinical sites; primary outcome: coronary artery diameter. | Postmenopausal on current estrogen therapy, 1 or more coronary stenoses >30% of luminal diameter. | Not stated | Breast or endometrial cancer; previous or planned coronary bypass surgery; history of DVT or PE; uncontrolled hypertension or diabetes. | 309 | CEE=100/CEE/MPA= 104/placebo=105 | 65.8 Range 42-80 yrs | CEE 0.625 mg or CEE 0.625/MPA 2.5 mg | Identical placebo | Not stated; pill count | DVT and PE not specified outcomes | Not stated | 3 yrs | 80% | VTE= 3.70 (0.45-30.44)** | P=0.16 | Fair: VTE reported as adverse experience. Method of VTE diagnosis not described.

*Not all exclusions listed

**calculated

CEE indicates Conjugated eqne estrogen; DVT, Deep Vein Thrombosis; HRT, Hormone Replacement Therapy; MPA, Medroxyprogestone acetate; PE,

Evidence Table 2. HRT and Venous Thromboembolism--Case-Control StudiesAppendix 4

Author, year | Setting/Population | Selection of cases | Selection of controls | No. Cases/Controls | Selected Exclusions* | Age range | Hormone type/dosage(s) | Duration of estrogen use | Progestin use | Definition of HRT/ERT exposure usage | Method of determining exposure | Method of outcome measurement | Confounders controlled for | Confounders not controlled for | Adjusted OR (95% CI) | Exposed cases | Duration trends | Number Needed to Harm | Quality of studies
Devor, 1992^ 17 ^ | University hospital; San Diego, CA | VTE by hospital discharge diagnosis | Hospitalized on same service, matched to age and hospitalization date | 121/236 | Not specified | > 45yrs | CEE/0.625, 1.25 mg; Transdermal estradiol/25, 50, 100 mcg | Not specified | Not specified | Current=HRT use at time of admission; Nonuser not defined | Chart review | Clinical exam diagnostic procedure | None | Body mass index, varicose veins, smoking | VTE 0.79 (0.30-2.08) | 6 | Not analyzed | Not able to calculate | Poor: not accurate ascertainment of cases, included VTE cases not present at admission; important confounders not included, significant difference between hospital length of stay between cases and controls.
Daly, 1996^ 6 ^ | Hospital based; UK | First time VTE | Hospitalized for diagnosis unrelated to HRT | 103/178 | History of VTE; surgery, trauma, pregnancy, bedrest within prior 6 wks; use of anticoagulants or oral contraceptives | 45-64 yrs | CEE/0.625 mg; Estradiol/1mg, 2mg; EE/1.5 mg; Transdermal/50, 100 mcg | 1-12 mos, 13-36 mos, 37-60 mos, 61 or more mos | Dosage/type not specified | Current=HRT use within months prior to admission; Nonuser=never or past user | Interview | Admitting diagnosis | Body mass index, varicose veins, socioeconomic group | Smoking | VTE 3.5 (1.8-7.0) | 44 | Highest risk with first year of use | 6,060 woman yrs/1 VTE | Fair: did not control for smoking; 22 cases recrted retrospectively; analysis of dosages, route, and ERT/HRT based on small numbers.
Daly, 1996^ 7 ^ | Hospital based; UK | First time VTE | Hospitalized for diagnosis unrelated to HRT | 18/161 | Same as above | 45-64 yrs | Not specified | Not specified | Dosage/type not specified | Current=HRT use within months prior to admission; Nonuser=never or past user | Interview | PE: V/Q scan; pulmonary angiogram clinical exam DVT: venography, duplex scanning, radioisotope studies, clinical exam | Body mass index, socioeconomic group | Smoking, varicose veins | VTE 2.3 (0.6-8.1) | 4 | Not analyzed | Not able to calculate | Poor: type and dose of HRT not included; not peer reviewed, published as letter to editor.
Jick, 1996^ 8 ^ | Group Health Plan; Seattle, WA | First VTE diagnosis and positive study for DVT or PE and treatment with heparin and oral anticoagulants | Random within study cohort, matched to age and index date of case | 42/168 | History of prior VTE; trauma/surgery 6 mos prior to VTE | 50-74 yrs | CEE or EE/0.325, 0.625, 1.25 mg | 1 yr or less, 1.1-4.9 yrs, 5 yrs or more | Dosage/type not specified | Current=ERT within prior 6 mos; Nonusers=ever users or past users | Pharmacy records | PE: V/Q scan; DVT: venogram, ultrasound, doppler and treatment with anticoagulants | Body mass index, smoking, varicose veins | Not Stated | VTE 3.6 (1.6-7.8) DVT 4.0 (1.6-9.7) PE 2.5 (0.5-12.2) | 21 | Highest risk with first year of use | 4,347 woman yrs/1 VTE | Good: although analysis of dosages and ERT/HRT were based on small numbers and method of determining exposure was through formulary records.
Perez-Gutthann, 1997^ 9 ^ | Population based within General Practice Research Database, UK | First time VTE with hospital admission | Random within study cohort | 292/10,000 | History of VTE, coagulopathy; recent fracture, injury, sugery, hospital admission | 50-79 yrs | CEE/0.625, 1.25 mg; Transdermal estradiol/25, 50, 100 mcg | 1-6 mos, 6-12 mos, >12 mos | Dosage/type not specified | Current=HRT use within 6 mos; Nonuser=no prescription in database; Past user=no HRT within 6 mos | National Formulary | Discharge diagnosis, clinical symoptoms and diagnostic procedures | Body mass index, smoking, varicose veins/superficial phlebitis, age, oophorectomy status | Not Stated | 2.1 (1.4-3.2) Current vs. Nonuser | 37 | Highest risk with first year of use | 6,993 woman yrs/1 VTE | Good: although analysis of dosages and ERT/HRT were based on small numbers and method of determining exposure was through formulary records.
Varas-Lorenzo, 1998^ 10 ^ | Population based within Regional Health System; Italy | First time VTE by hospital discharge diagnosis | Random within study cohort | 171/10,000 | History of VTE, coagulopathies, pregnancy | 45-79 yrs | Transdermal 79% Oral 21% | Nonuse, 1-12 mos, >12 mos | Dosage/type not specified | Current=Prescription within past 6 mos; Nonuser=no prescription on record; Past=Prescription >6 mos ago | Prescription database | Clinical signs and symptoms and positive diagnostic procedure, or necropsy, or treatment with anticoagulants | Body mass index, history of varicose veins or superficial phlebitis, hypertension, diabetes, age, osteoarthritis | Smoking | 2.3 (1.0-5.3) Current vs. Nonuser | 6 | Highest risk with first year of use | 5,000 woman yrs/1 VTE | Fair: did not include smoking, analysis based on 6 current users of ERT/HRT.
Høibraaten, 1999^ 13 ^ | University hospital; Oslo, Norway | VTE by hospital discharge diagnosis | Random within population of Oslo | 176/352 | Any cancer diagnosis | 45-70 yrs; Mean 59 yrs | Estradiol in various formulations | <12 mos, >12mos | Dosage/type not specified | Current=HRT use at time of admission; Nonuse not defined | Cases-chart review and questionnaire Controls-questionnaire | Venography n=135; V/Q scan n=33; Ultrasound n=7; pulmonary angiography n=2; autopsy n=9; clinical dx n=2 | Hypertension, diabetes, coronary artery disease, smoking, prior VTE, body mass index | Varicose veins | 1.22 (0.76 - 1.94) Current vs. Nonuser | 50 | Highest risk with first year of use | Not analyzed | Fair: no clear method of outcome measurement. Dose of HRT not reported.
Boston Collaborative, (1974)^ 3 ^ | 24 Boston area hospitals | VTE by hospital discharge diagnosis | Hospitalized for diagnosis unrelated to HRT | 18/774 | History of VTE; post-op or post-traumatic VTE | 45-69 yrs | Not specified | Not specified | Not specified | Not specified | Interview | DVT: not specified; PE: lung scan, or angiography or surgery | None | Body mass index, varicose veins, smoking | 2.26 (0.61 - 8.41)** | 3 | Not analyzed | 25,000 | Poor: No clear method of outcome measurement. Dose and duration of HRT use not reported. Confounders not controlled for.

*Not all exclusions listed

**calculated

CE indicates Conjugated estrogen; EE, Esterified; ERT, Estrogen Replacement Therapy; HRT, Hormone Replacement Therapy; PE, Pulmonary Emolism;

Evidence Table 3. HRT and Venous Thromboembolism--Cohort Studies (51 of 1)Appendix 4

Author, Year | Grodstein, 1996^ 11 ^
Study type | Prospective
Population | 112,593 nurses
Setting | 11 U.S. states
Exclusions* | History of PE
Age range | 30-55 yrs in 1976
Method of Determining Exposure | Questionnaire every 2 yrs
Definition of HRT Use | Current Past Never
HRT Dosage(s) | CEE: 0.3 mg; 0.625 mg; 1.25 mg
Progestin Use | Not specified
Outcome Measured | PE
Method of Determining Outcome | V/Q scan, pulmonary angiogram or necropsy
Study Duration | 16 yrs
Follow-up Rate | Estimated > 90%
Confounders Controlled For | Age, body mass index, hypertension, diabetes, smoking, oral contraceptive use, parity, elevated cholesterol
Current Users with PE (n) | 30-39 yrs n=1 40-49 yrs n=4 50-59 yrs n=10 >60 yrs n=7
Past Users with PE (n) | 30-39 yrs n=0 40-49 yrs n=4 50-59 yrs n=8 >60 yrs n=7
Current User Relative Risk (95% CI) | 2.1 (1.2-3.8)
Past User Relative Risk (95% CI) | 1.3 (0.7-2.4)
Relative Risk by duration of usage | Current user: >5 yrs =1.9 (0.9-4.0); Current user: < 5 yrs =2.6 (1.2-5.2)
Number Needed to Harm | Current user: 17,932 woman yrs/1 VTE; Past user: 27,691 woman yrs/1VTE
Quality of Study | Good-No trends observed in dosages. Relative risk slightly increased when venous diagnoses excluded

*Not all exclusions listed

Note: CEE indicates Conjugated eqne estrogen; PE, Pulmonary Embolism; VTE, Venous Thromboembolism

Evidence Table 4. SERMS and Venous Thromboembolism--Randomized Controlled TrialsAppendix 4

Author, Year | Setting/Population | Eligibility | Number Considered | Exclusions | Number Randomized | Treatment (n) Placebo (n) | Mean Age | SERM Type/Dosage(s) | Placebo RX | Compliance Rate/Method | Secondary Outcome Measured | Method of Secondary Outcome Measurement | Study Duration | Follow-up Rate | Relative Risk (95% CI) | Number Needed to Harm | Quality of Studies
Tamoxifen
Fisher (BCPT), 1998^ 20 ^ | Outpatient;131 U.S. and Canadian sites | No breast cancer and 60 yrs or older, or 35-59 yrs with increased risk for breast cancer | 98,018 | Breast cancer;use of HRT, oral contraceptives, or androgens within 3 mos of randomization; history of VTE or PE | 13,388 | 6,681/6,707 | 39% 35-49yrs 30% 50-59 yrs 30% > 60 yrs | Tamoxifen 20 mg/d | Placebo | Not stated | DVT and PE not specified outcomes | Not stated | 5 years | 92.3% tamoxifen 92.4% placebo | PE 3.01 (1.15-9.27) DVT 1.60 (0.91-2.86) VTE 1.91 (1.21-3.02) | 266 woman yrs/1 VTE | Fair: diagnostic criteria for VTE unclear.
Powles, 1998^ 22 ^ | Outpatient Breast Clinic; Great Britain | Age 30-70 yrs and increased risk for breast cancer due to family history | 2,508 | History of any cancer, DVT, or PE | 2,494 | 1,250/1,244 | Median age 47 yrs | Tamoxifen 20 mg/d | Identical placebo | Interview, confirmed by random blood testing of tamoxifen group | DVT and PE not specified outcomes | Not stated | Interim analysis at 70 months | 89% | Unadjusted OR 1.75 (0.51-5.98)* | 419 woman yrs/1 VTE | Poor: VTE not designated as a secondary outcome; diagnostic criteria for VTE unclear; important loss to follow-up.
Veronesi, 1998^ 21 ^ | Outpatient; mostly Italian sites | Age 35-70 yrs with hysterectomy | 13,419 | Severe illness, cardiac disease, endometriosis, history of DVT | 5,408 | 2,700/2,708 | Median age 51 yrs | Tamoxifen 20 mg/d | Identical placebo | Not stated | DVT and PE not specified outcomes | Not stated | Interim analysis at 46 months | >90% | Unadjusted OR 1.76 (0.51-6.01)* | 896 woman yrs/1 VTE | Poor: VTE not designated as a secondary outcome;diagnostic criteria for VTE unclear; high dropout rate.
Raloxifene
Lufkin, 1998^ 24 ^ | Outpatient; two U.S. sites | Age 45-75 yrs, postmenopausal | not available | History of DVT, thromboembolic diagnoses, cancer, coronary disease | 143 | 48 (60 mg)/47 (120 mg)/48 (placebo) | 68 yrs | Raloxifene 60 mg/d or 120 mg/d + calcium 750 mg/d and Vitamin D | Calcium 750 mg/d and Vitamin D | Not stated | DVT and PE not specified outcomes | Not stated | One year | >90% | Undefined | Undefined | Poor: VTE not designated as a secondary outcome; diagnostic criteria for VTE unclear; underpowered to detect VTE outcome.
Cummings (MORE), 1999^ 23 ^ | 180 community and medical clinics; mainly U.S. and Europe | Age <80 yrs; 2 yrs postmenopausal with osteoporosis | 22,379 | History of breast or endometrial cancer, stroke, VTE, any cancer; abnormal uterine bleeding; secondary causes osteoporosis | 7,705 | 5,129/2,576 | 65 yrs | Raloxifene 60 mg/d or 120 mg/d + calcium 500 mg/d and 400-600 IU cholecalciferol | Placebo + Calcium 500 mg/d and 400-600 IU cholecalciferol | 92% took > 80% medication; method not stated | DVT and PE not specified outcomes; reported as adverse effect | Chart review | 40 months | At 3 yrs: 78% raloxifene 75% placebo | VTE 3.1 (1.5-6.2) | 155 woman yrs/1 VTE | Fair: VTE not designated as an apriori outcome.

*Calculated

Note: DVT indicates Deep Vein Thrombosis; HRT, Hormone Replacement Therapy;