# Appendix 2. Hormone Replacement Therapy and Venous Thromboembolism Search Results

MEDLINE 1966 to December 2000

HealthSTAR 1975 to December 2000

Cochrane Controlled Trials Register

[image]