# Appendix 1c. Search Strategy for Selective Estrogen Receptor Modulators (SERMs)

1. (tamoxifen or raloxifene).mp.
2. Bone density/or "bone density".mp.
3. exp osteoporosis/or "osteoporosis".mp.
4. exp fractures/or fracture$.mp.
5. exp hormone replacement therapy/
6. estrogen replacement.mp.
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7
9. limit 8 to (human and english language)
10. exp breast neoplasms/
11. 9 not 10
12. from 11 keep