# Appendix 1b. Search Strategy for Hormone Replacement Therapy Randomized Controlled Trials

1 exp hormone replacement therapy estrogen replacement therapy

2 hormone replacement.tw. (text word taken from title and abstract of article)

3 estrogen replacement.tw.

4 exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)

eqlenin | estrogens, catechol
eqlin | estrogens, conjugated
estradiol | estrogens, non-steroidal
estriol | estrone

5 exp estrogens, synthetic/ad,tu

estrogens, non-steroidal epimestrol
chlorotrianisene | ethinyl estradiol
coumestrol | mestranol
dienestrol | qnestrol
diethylstilbestrol | hexestrol
zearalenone | zeranol

6 1 or 2 or 3 or 4 or 5

7 limit 6 to randomized controlled trials (check for document type)

8 randomized controlled trials

9 randomized.tw.

10 8 or 9

11 6 and 10

12 7 or 11

13 limit 12 to human

14 limit 13 to english language

15 looked at english abstracts of foreign articles