# Appendix 1a. Search Strategy for Effects of Hormone Replacement Therapy on Coagulation

1 exp hormone replacement therapy estrogen replacement therapy

2 hormone replacement.tw. (Text word from title and abstract of article)

3 estrogen replacement.tw.

4 exp estrogens/ad,tu (ad = administration & dosage)

| (tu = therapeutic use)
eqlenin | estrogens, catechol
eqlin | estrogens, conjugated
estradiol | estrogens, non-steroidal
estrone | estriol
estramustine | chlorotrianisene
coumestrol | dienestrol
diethylstilbestrol | hexestrol
zearalenone | zeranol

5 exp estrogens, synthetic/ad,tu

epimestrol | ethinyl estradiol
mestranol | qnestrol

6 1 or 2 or 3 or 4 or 5

7 exp blood coagulation disorders

antithrombin 111 deficiency | disseminated intravascular coagulation
Bernard-Soulier syndrome | platelet storage pool deficiency
protein C deficiency | coagulation protein disorders
protein S deficiency | purpura, thrombocytopenic
thrombasthenia | thrombocythemia, hemorrhagic
vitamin K deficiency

8 exp blood coagulation fibrinolysis

9 hypercoagulation.tw.

10 exp hemostasis blood coagulation platelet activation

11 exp thromboembolism cerebral embolism and thrombosis embolism, paradoxical

12 thrombophlebitis

13 pulmonary embolism

14 exp fibrinogen

fibrinogens, abnormal | fibrin fibrinogen degradation products
fibrinopeptide A | fibrinopeptide B

15 fibrinolysis

16 blood clot$.tw.

17 exp thrombosis

coronary thrombosis | purpura, thrombotic thrombocytopenic
thromboembolism | venous thrombosis

18 regional blood flow

19 blood flow velocity

20 exp anticoagulants

4-hydroxycoumarins | acenocoumarol | ancrod
citric acid | coumarins | dermatan sulfate
dextran sulfate | dextrans | dicumarol
edetic acid | enoxaparin | ethyl biscoumacetate
gabexate | heparin | heparin, low-molecular weight
heparinoids | nadroparin | pentosan sulfuric polyester
phenindione | phenprocoumon | protein C
protein S | tedelparin | tetrathionic acid
warfarin

21 thrombo$.tw.

22 thrombolytic therapy

23 exp hemorrhage

blood loss, surgical | ecchymosis | cerebral hemorrhage
epitaxis | eye hemorrhage | gastrointestinal hemorrhage
hemarthrosis | hematocele | hematoma
hematuria | hemobilia | hemoperitoneum
hemoptysis | hemothorax | postoperative hemorrhage
retrobulbar hemorrhage purpura | shock, hemorrhagic
uterine hemorrhage

24 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23

25 6 and 24

26 limit 25 to human

27 limit 26 to english language

28 (looked at english abstracts for foreign language articles)