# References

1 U.S. Preventive Services Task Force. Screening for abdominal aortic aneurysm: recommendation statement. Ann Intern Med. 2005;142(3):198-202. [pmid: 15684208].
2 Johns Hopkins Medicine. Abdominal Aneurysm. Baltimore, MD. The Johns Hopkins University. 2013. Accessed at http://www.hopkinsmedicine.org/vascular/conditions/Abdominal on 7 January 2013.
3 VascularWeb®. Abdominal Aortic Aneurysm. Chicago. Society for Vascular Surgery. 2011. Accessed at http://www.vascularweb.org/vascularhealth/Pages/abdominal-aortic-aneurysm.aspx?PF=1 on 7 January 2013.
4 Moll FL, Powell JT, Fraedrich G, et al. Management of abdominal aortic aneurysms: clinical practice guidelines of the European Society for Vascular Surgery. Eur J Vasc Endovasc Surg. 2011;41(Suppl 1):S1-58. [pmid: 21215940].
5 Wanhainen A. How to define an abdominal aortic aneurysm—influence on epidemiology and clinical practice. Scand J Surg. 2008;97(2):105-9. [pmid: 18575024].
6 Wanhainen A, Svensjo S, Mani K. Screening for abdominal aortic aneurysm—areas where information is still inadequate. Scand J Surg. 2008;97(2):131-5. [pmid: 18575030].
7 Cornuz J, Sidoti PC, Tevaearai H, et al. Risk factors for asymptomatic abdominal aortic aneurysm: systematic review and meta-analysis of population-based screening studies. Eur J Public Health. 2004;14(4):343-9. [pmid: 15542867].
8 Jamrozik K, Norman PE, Spencer CA, et al. Screening for abdominal aortic aneurysm: lessons from a population-based study. Med J Aust. 2000;173(7):345-50. [pmid: 11062788].
9 Conway AM, Malkawi AH, Hinchliffe RJ, et al. First-year results of a national abdominal aortic aneurysm screening programme in a single centre. Br J Surg. 2012;99(1):73-7. [pmid: 21928466].
10 Schermerhorn M, Zwolak R, Velazquez O, et al. Ultrasound screening for abdominal aortic aneurysm in medicare beneficiaries. Ann Vasc Surg. 2008;22(1):16-24. [pmid: 18055170].
11 Svensjo S, Bjorck M, Gurtelschmid M, et al. Low prevalence of abdominal aortic aneurysm among 65-year-old Swedish men indicates a change in the epidemiology of the disease. Circulation. 2011;124(10):1118-23. [pmid: 21844079].
12 Derubertis BG, Trocciola SM, Ryer EJ, et al. Abdominal aortic aneurysm in women: prevalence, risk factors, and implications for screening. J Vasc Surg. 2007;46(4):630-5. [pmid: 17903646].
13 Ashton HA, Buxton MJ, Day NE, et al. The Multicentre Aneurysm Screening Study (MASS) into the effect of abdominal aortic aneurysm screening on mortality in men: a randomised controlled trial. Lancet. 2002;360(9345):1531-9. [pmid: 12443589].
14 Scott RA, Wilson NM, Ashton HA, et al. Influence of screening on the incidence of ruptured abdominal aortic aneurysm: 5-year results of a randomized controlled study. Br J Surg. 1995;82(8):1066-70. [pmid: 7648155].
15 Lindholt JS, Juul S, Fasting H, et al. Screening for abdominal aortic aneurysms: single centre randomised controlled trial. BMJ. 2005;330(7494):750. [pmid: 15757960].
16 Norman PE, Jamrozik K, Lawrence-Brown MM, et al. Population based randomised controlled trial on impact of screening on mortality from abdominal aortic aneurysm. BMJ. 2004;329(7477):1259. [pmid: 15545293].
17 Darwood R, Earnshaw JJ, Turton G, et al. Twenty-year review of abdominal aortic aneurysm screening in men in the county of Gloucestershire, United Kingdom. J Vasc Surg. 2012;56(1):8-13. [pmid: 22503187].
18 National Health Service. NHS Abdominal Aortic Aneurysm Screening Programme: 2011–12 Summary. London. National Health Service. 2013.
19 Sandiford P, Mosquera D, Bramley D. Trends in incidence and mortality from abdominal aortic aneurysm in New Zealand. Br J Surg. 2011;98(5):645-51. [pmid: 21381003].
20 Vardulaki KA, Walker NM, Day NE, et al. Quantifying the risks of hypertension, age, sex and smoking in patients with abdominal aortic aneurysm. Br J Surg. 2000;87(2):195-200. [pmid: 10671927].
21 Duncan JL, Wolf B, Nichols DM, et al. Screening for abdominal aortic aneurysm in a geographically isolated area. Br J Surg. 2005;92(8):984-8. [pmid: 16034847].
22 Palombo D, Lucertini G, Pane B, et al. District-based abdominal aortic aneurysm screening in population aged 65 years and older. J Cardiovasc Surg. 2010;51(6):777-82. [pmid: 21124273].
23 Bush RL, Lin PH, Lumsden AB. Endovascular management of abdominal aortic aneurysms. J Cardiovasc Surg. 2003;44(4):527-34. [pmid: 14627225].
24 Chaikof EL, Brewster DC, Dalman RL, et al. The care of patients with an abdominal aortic aneurysm: the Society for Vascular Surgery practice guidelines. J Vasc Surg. 2009;50(4 Suppl):S2-49. [pmid: 19786250].
25 Scott RA, Bridgewater SG, Ashton HA. Randomized clinical trial of screening for abdominal aortic aneurysm in women. Br J Surg. 2002;89(3):283-5. [pmid: 11872050].
26 Agency for Healthcare Research and Quality. Healthcare Cost and Utilization Project: Nationwide Inpatient Sample Data Set. Report No. 43. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
27 Lederle FA, Nelson DB, Joseph AM. Smokers' relative risk for aortic aneurysm compared with other smoking-related diseases: a systematic review. J Vasc Surg. 2003;38(2):329-34. [pmid: 12891116].
28 Stolle K, Berges A, Lietz M, et al. Cigarette smoke enhances abdominal aortic aneurysm formation in angiotensin II-treated apolipoprotein E-deficient mice. Toxicol Lett. 2010;199(3):403-9. [pmid: 20937366].
29 Laughlin GA, Allison MA, Jensky NE, et al. Abdominal aortic diameter and vascular atherosclerosis: the Multi-Ethnic Study of Atherosclerosis. Eur J Vasc Endovasc Surg. 2011;41(4):481-7. [pmid: 21236707].
30 Trollope AF, Golledge J. Angiopoietins, abdominal aortic aneurysm and atherosclerosis. Atherosclerosis. 2011;214(2):237-43. [pmid: 20832800].
31 Abdul-Hussien H, Hanemaaijer R, Kleemann R, et al. The pathophysiology of abdominal aortic aneurysm growth: corresponding and discordant inflammatory and proteolytic processes in abdominal aortic and popliteal artery aneurysms. J Vasc Surg. 2010;51(6):1479-87. [pmid: 20488324].
32 Kaneko H, Anzai T, Morisawa M, et al. Resveratrol prevents the development of abdominal aortic aneurysm through attenuation of inflammation, oxidative stress, and neovascularization. Atherosclerosis. 2011;217(2):350-7. [pmid: 21530968].
33 Thompson AR, Drenos F, Hafez H, et al. Candidate gene association studies in abdominal aortic aneurysm disease: a review and meta-analysis. Eur J Vasc Endovasc Surg. 2008;35(1):19-30. [pmid: 17920311].
34 Nordon IM, Hinchliffe RJ, Holt PJ, et al. Review of current theories for abdominal aortic aneurysm pathogenesis. Vascular. 2009;17(5):253-63. [pmid: 19769804].
35 Collin J, Heather B, Walton J. Growth rates of subclinical abdominal aortic aneurysms—implications for review and rescreening programmes. Eur J Vasc Surg. 1991;5(2):141-4. [pmid: 2037085].
36 Powell JT, Sweeting MJ, Brown LC, et al. Systematic review and meta-analysis of growth rates of small abdominal aortic aneurysms. Br J Surg. 2011;98(5):609-18. [pmid: 21412998].
37 Wilmink AB, Quick CR. Epidemiology and potential for prevention of abdominal aortic aneurysm. Br J Surg. 1998;85(2):155-62. [pmid: 9501808].
38 Reed WW, Hallett JW Jr, Damiano MA, et al. Learning from the last ultrasound. A population-based study of patients with abdominal aortic aneurysm. Arch Intern Med. 1997;157(18):2064-8. [pmid: 9382661].
39 Scott RA, Tisi PV, Ashton HA, et al. Abdominal aortic aneurysm rupture rates: a 7-year follow-up of the entire abdominal aortic aneurysm population detected by screening. J Vasc Surg. 1998;28(1):124-8. [pmid: 9685138].
40 Conway KP, Byrne J, Townsend M, et al. Prognosis of patients turned down for conventional abdominal aortic aneurysm repair in the endovascular and sonographic era: Szilagyi revisited?. J Vasc Surg. 2001;33(4):752-7. [pmid: 11296328].
41 Powell JT. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. May. 9. 2002;346(19):1445-52. [pmid: 12000814].
42 Wilmink AB, Hubbard CS, Day NE, et al. The incidence of small abdominal aortic aneurysms and the change in normal infrarenal aortic diameter: implications for screening. Eur J Vasc Endovasc Surg. 2001;21(2):165-70. [pmid: 11237791].
43 Thompson AR, Cooper JA, Ashton HA, et al. Growth rates of small abdominal aortic aneurysms correlate with clinical events. Br J Surg. 2010;97(1):37-44. [pmid: 20013940].
44 Fleming C, Whitlock EP, Beil TL, et al. Screening for abdominal aortic aneurysm: a best-evidence systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2005;142(3):203-11. [pmid: 15684209].
45 van Vlijmen-van Keulen CJ, Pals G, Rauwerda JA. Familial abdominal aortic aneurysm: a systematic review of a genetic background. Eur J Vasc Endovasc Surg. 2002;24(2):105-16. [pmid: 12389231].
46 Larsson E, Granath F, Swedenborg J, et al. A population-based case-control study of the familial risk of abdominal aortic aneurysm. J Vasc Surg. 2009;49(1):47-50. [pmid: 19028058].
47 MacSweeney ST, O'Meara M, Alexander C, et al. High prevalence of unsuspected abdominal aortic aneurysm in patients with confirmed symptomatic peripheral or cerebral arterial disease. Br J Surg. 1993;80(5):582-4. [pmid: 8518892].
48 Lederle FA, Johnson GR, Wilson SE, et al. Relationship of age, gender, race, and body size to infrarenal aortic diameter. The Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Investigators. J Vasc Surg. 1997;26(4):595-601. [pmid: 9357459].
49 Helgadottir A, Thorleifsson G, Magnusson KP, et al. The same sequence variant on 9p21 associates with myocardial infarction, abdominal aortic aneurysm and intracranial aneurysm. Nat Genet. 2008;40(2):217-24. [pmid: 18176561].
50 Lederle FA, Johnson GR, Wilson SE, et al. The aneurysm detection and management study screening program: validation cohort and final results. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. 2000;160(10):1425-30. [pmid: 10826454].
51 Sweeting MJ, Thompson SG, Brown LC, et al. Meta-analysis of individual patient data to examine factors affecting growth and rupture of small abdominal aortic aneurysms. Br J Surg. 2012;99(5):655-65. [pmid: 22389113].
52 Lederle FA, Johnson GR, Wilson SE, et al. Rupture rate of large abdominal aortic aneurysms in patients refusing or unfit for elective repair. JAMA. 2002;287(22):2968-72. [pmid: 12052126].
53 Darling RC, Messina CR, Brewster DC, et al. Autopsy study of unoperated abdominal aortic aneurysms. The case for early resection. Circulation. 1977;56(3 Suppl):ii161-4. [pmid: 884821].
54 Brown LC, Powell JT. Risk factors for aneurysm rupture in patients kept under ultrasound surveillance. UK Small Aneurysm Trial Participants. Ann Surg. 1999;230(3):289-96. [pmid: 10493476].
55 Cronenwett JL, Murphy TF, Zelenock GB, et al. Actuarial analysis of variables associated with rupture of small abdominal aortic aneurysms. Surgery. 1985;98(3):472-83. [pmid: 3898453].
56 Fillinger MF, Raghavan ML, Marra SP, et al. In vivo analysis of mechanical wall stress and abdominal aortic aneurysm rupture risk. J Vasc Surg. 2002;36(3):589-97. [pmid: 12218986].
57 Venkatasubramaniam AK, Fagan MJ, Mehta T, et al. A comparative study of aortic wall stress using finite element analysis for ruptured and non-ruptured abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2004;28(2):168-76. [pmid: 15234698].
58 Brown PM, Zelt DT, Sobolev B. The risk of rupture in untreated aneurysms: the impact of size, gender, and expansion rate. J Vasc Surg. 2003;37(2):280-4. [pmid: 12563196].
59 Lederle FA, Walker JM, Reinke DB. Selective screening for abdominal aortic aneurysms with physical examination and ultrasound. Arch Intern Med. 1988;148(8):1753-6. [pmid: 3041938].
60 Lindholt JS, Vammen S, Juul S, et al. The validity of ultrasonographic scanning as screening method for abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. 1999;17(6):472-5. [pmid: 10375481].
61 Costantino TG, Bruno EC, Handly N, et al. Accuracy of emergency medicine ultrasound in the evaluation of abdominal aortic aneurysm. J Emerg Med. 2005;29(4):455-60. [pmid: 16243207].
62 Tayal VS, Graf CD, Gibbs MA. Prospective study of accuracy and outcome of emergency ultrasound for abdominal aortic aneurysm over two years. Acad Emerg Med. 2003;10(8):867-71. [pmid: 12896888].
63 Quill DS, Colgan MP, Sumner DS. Ultrasonic screening for the detection of abdominal aortic aneurysms. Surg Clin North Am. 1989;69(4):713-20. [pmid: 2501880].
64 Graeve AH, Carpenter CM, Wicks JD, et al. Discordance in the sizing of abdominal aortic aneurysm and its significance. Am J Surg. 1982;144(6):627-34. [pmid: 7149120].
65 Long A, Rouet L, Lindholt JS, et al. Measuring the maximum diameter of native abdominal aortic aneurysms: review and critical analysis. Eur J Vasc Endovasc Surg. 2012;43(5):515-24. [pmid: 22336051].
66 Norman PE, Jamrozik K, Lawrence-Brown MM, et al. Western Australian randomized controlled trial of screening for abdominal aortic aneurysm. Br J Surg. 2003;90(4):492.
67 Lindholt JS, Juul S, Fasting H, et al. Hospital costs and benefits of screening for abdominal aortic aneurysms. Results from a randomised population screening trial. Eur J Vasc Endovasc Surg. 2002;23(1):55-60. [pmid: 11748949].
68 Lederle FA, Wilson SE, Johnson GR, et al. Variability in measurement of abdominal aortic aneurysms. Abdominal Aortic Aneurysm Detection and Management Veterans Administration Cooperative Study Group. J Vasc Surg. 1995;21(6):945-52. [pmid: 7776474].
69 Zarnke MD, Gould HR, Goldman MH. Computed tomography in the evaluation of the patient with symptomatic abdominal aortic aneurysm. Surgery. 1988;103(6):638-42. [pmid: 3375990].
70 Fink HA, Lederle FA, Roth CS, et al. The accuracy of physical examination to detect abdominal aortic aneurysm. Arch Intern Med. 2000;160(6):833-6. [pmid: 10737283].
71 Lederle FA, Simel DL. The rational clinical examination. Does this patient have abdominal aortic aneurysm?. JAMA. 1999;281(1):77-82. [pmid: 9892455].
72 Brown LC, Greenhalgh RM, Thompson SG, et al. Does EVAR alter the rate of cardiovascular events in patients with abdominal aortic aneurysm considered unfit for open repair? Results from the randomised EVAR trial 2. Eur J Vasc Endovasc Surg. 2010;39(4):396-402. [pmid: 20096611].
73 Grootenboer N, Hendriks JM, Cuypers PW, et al. Endovascular abdominal aortic aneurysm repair in women. Acta Chir Belg. 2011;111(1):2-6. [pmid: 21520779].
74 Parodi JC, Palmaz JC, Barone HD. Transfemoral intraluminal graft implantation for abdominal aortic aneurysms. Ann Vasc Surg. 1991;5(6):491-9. [pmid: 1837729].
75 Karthikesalingam A, Al-Jundi W, Jackson D, et al. Systematic review and meta-analysis of duplex ultrasonography, contrast-enhanced ultrasonography or computed tomography for surveillance after endovascular aneurysm repair. Br J Surg. 2012;99(11):1514-23. [pmid: 23001681].
76 Greenhalgh RM, Brown LC, Kwong GP, et al. Comparison of endovascular aneurysm repair with open repair in patients with abdominal aortic aneurysm (EVAR trial 1), 30-day operative mortality results: randomised controlled trial. Lancet. 2004;364(9437):843-8. [pmid: 15351191].
77 EVAR Trial Participants. Endovascular aneurysm repair versus open repair in patients with abdominal aortic aneurym (EVAR trial 1): randomised controlled trial. Lancet. 2005;365(9478):2179-86. [pmid: 15978925].
78 United Kingdom EVAR Trial Investigators, Greenhalgh RM, Brown LC, et al. Endovascular versus open repair of abdominal aortic aneurysm. N Engl J Med. 2010;362(20):1863-71. [pmid: 20382983].
79 Lederle FA, Freischlag JA, Kyriakides TC, et al. Outcomes following endovascular vs open repair of abdominal aortic aneurysm: a randomized trial. JAMA. 2009;302(14):1535-42. [pmid: 19826022].
80 Prinssen M, Verhoeven EL, Buth J, et al. A randomized trial comparing conventional and endovascular repair of abdominal aortic aneurysms. N Engl J Med. 2004;351(16):1607-18. [pmid: 15483279].
81 Blankensteijn JD, de Jong SE, Prinssen M, et al. Two-year outcomes after conventional or endovascular repair of abdominal aortic aneurysms. N Engl J Med. 2005;352(23):2398-405. [pmid: 15944424].
82 EVAR Trial Participants. Endovascular aneurysm repair and outcome in patients unfit for open repair of abdominal aortic aneurysm (EVAR trial 2): randomised controlled trial. Lancet. 2005;365(9478):2187-92. [pmid: 15978926].
83 United Kingdom EVAR Trial Investigators, Greenhalgh RM, Brown LC. Endovascular repair of aortic aneurysm in patients physically ineligible for open repair. N Engl J Med. 2010;362(20):1872-80. [pmid: 20382982].
84 Fleming C, Whitlock E, Beil T, et al. Primary Care Screening for Abdominal Aortic Aneurysm. Evidence Synthesis No. 35. Rockville, MD. Agency for Healthcare Research and Quality. 2005. [pmid: 20722131].
85 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
86 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
87 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
88 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
89 Kim LG, P Scott RA, Ashton HA, et al. A sustained mortality benefit from screening for abdominal aortic aneurysm. Ann Intern Med. 2007;146(10):699-706. [pmid: 17502630].
90 Thompson SG, Ashton HA, Gao L, et al. Screening men for abdominal aortic aneurysm: 10 year mortality and cost effectiveness results from the randomised Multicentre Aneurysm Screening Study. BMJ. 2009;338:b2307. [pmid: 19553269].
91 Ashton HA, Gao L, Kim LG, et al. Fifteen-year follow-up of a randomized clinical trial of ultrasonographic screening for abdominal aortic aneurysms. Br J Surg. 2007;94(6):696-701. [pmid: 17514666].
92 Lindholt JS, Juul S, Fasting H, et al. Preliminary ten year results from a randomised single centre mass screening trial for abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. 2006;32(6):608-14. [pmid: 16893663].
93 Lindholt JS, Sorensen J, Sogaard R, et al. Long-term benefit and cost-effectiveness analysis of screening for abdominal aortic aneurysms from a randomized controlled trial. Br J Surg. 2010;97(6):826-34. [pmid: 20473995].
94 Lindholt JS, Vammen S, Fasting H, et al. Psychological consequences of screening for abdominal aortic aneurysm and conservative treatment of small abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2000;20(1):79-83. [pmid: 10906303].
95 Spencer CA, Norman PE, Jamrozik K, et al. Is screening for abdominal aortic aneurysm bad for your health and well-being?. ANZ J Surg. 2004;74(12):1069-75. [pmid: 15574151].
96 d'Audiffret A, Santilli S, Tretinyak A, et al. Fate of the ectatic infrarenal aorta: expansion rates and outcomes. Ann Vasc Surg. 2002;16(5):534-6. [pmid: 12183768].
97 Scott RA, Vardulaki KA, Walker NM, et al. The long-term benefits of a single scan for abdominal aortic aneurysm (AAA) at age 65. Eur J Vasc Endovasc Surg. 2001;21(6):535-40. [pmid: 11397028].
98 Devaraj S, Dodds SR. Ultrasound surveillance of ectatic abdominal aortas. Ann R Coll Surg Engl. 2008;90(6):477-82. [pmid: 18765027].
99 Hafez H, Druce PS, Ashton HA. Abdominal aortic aneurysm development in men following a “normal” aortic ultrasound scan. Eur J Vasc Endovasc Surg. 2008;36(5):553-8. [pmid: 18718773].
100 Lindholt JS, Vammen S, Juul S, et al. Optimal interval screening and surveillance of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2000;20(4):369-73. [pmid: 11035969].
101 Lederle FA, Johnson GR, Wilson SE, et al. Yield of repeated screening for abdominal aortic aneurysm after a 4-year interval. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. 2000;160(8):1117-21. [pmid: 10789604].
102 Emerton ME, Shaw E, Poskitt K, et al. Screening for abdominal aortic aneurysm: a single scan is enough. Br J Surg. 1994;81(8):1112-3. [pmid: 7953333].
103 Crow P, Shaw E, Earnshaw JJ, et al. A single normal ultrasonographic scan at age 65 years rules out significant aneurysm disease for life in men. Br J Surg. 2001;88(7):941-4. [pmid: 11442524].
104 Wanhainen A, Rosen C, Rutegard J, et al. Low quality of life prior to screening for abdominal aortic aneurysm: a possible risk factor for negative mental effects. Ann Vasc Surg. 2004;18(3):287-93. [pmid: 15354629].
105 Lucarotti ME, Heather BP, Shaw E, et al. Psychological morbidity associated with abdominal aortic aneurysm screening. Eur J Vasc Endovasc Surg. 1997;14(6):499-501. [pmid: 9467527].
106 Lederle FA, Wilson SE, Johnson GR, et al. Immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1437-44. [pmid: 12000813].
107 Lederle FA, Johnson GR, Wilson SE, et al. Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm. J Vasc Surg. 2003;38(4):745-52. [pmid: 14560224].
108 Powell JT, Brady AR, Brown LC, et al. Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. The UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1649-55. [pmid: 9853436].
109 Powell JT, Brown LC, Forbes JF, et al. Final 12-year follow-up of surgery versus surveillance in the UK Small Aneurysm Trial. Br J Surg. 2007;94(6):702-8. [pmid: 17514693].
110 Brown LC, Thompson SG, Greenhalgh RM, et al. Fit patients with small abdominal aortic aneurysms (AAAs) do not benefit from early intervention. J Vasc Surg. 2008;48(6):1375-81. [pmid: 19118733].
111 Fowkes FG, Greenhalgh RM, Powell JT, et al. Length of hospital stay following elective abdominal aortic aneurysm repair. U.K. Small Aneurysm Trial Participants. Eur J Vasc Endovasc Surg. 1998;16(3):185-91. [pmid: 9787298].
112 Sun Z. Diagnostic value of color duplex ultrasonography in the follow-up of endovascular repair of abdominal aortic aneurysm. J Vasc Interv Radiol. 2006;17(5):759-64. [pmid: 16687740].
113 Cao P, De Rango P, Verzini F, et al. Comparison of surveillance versus aortic endografting for small aneurysm repair (CAESAR): results from a randomised trial. Eur J Vasc Endovasc Surg. 2011;41(1):13-25. [pmid: 20869890].
114 De Rango P, Verzini F, Parlani G, et al. Quality of life in patients with small abdominal aortic aneurysm: the effect of early endovascular repair versus surveillance in the CAESAR trial. Eur J Vasc Endovasc Surg. 2011;41(3):324-31. [pmid: 21145269].
115 Ouriel K, Clair DG, Kent KC, et al. Endovascular repair compared with surveillance for patients with small abdominal aortic aneurysms. J Vasc Surg. 2010;51(5):1081-7. [pmid: 20304589].
116 Propanolol Aneurysm Trial Investigators. Propranolol for small abdominal aortic aneurysms: results of a randomized trial. J Vasc Surg. 2002;35(1):72-9. [pmid: 11802135].
117 Lindholt JS, Henneberg EW, Juul S, et al. Impaired results of a randomised double blinded clinical trial of propranolol versus placebo on the expansion rate of small abdominal aortic aneurysms. Int Angiol. 1999;18(1):52-7. [pmid: 10392481].
118 Mosorin M, Juvonen J, Biancari F, et al. Use of doxycycline to decrease the growth rate of abdominal aortic aneurysms: a randomized, double-blind, placebo-controlled pilot study. J Vasc Surg. 2001;34(4):606-10. [pmid: 11668312].
119 Karlsson L, Gnarpe J, Bergqvist D, et al. The effect of azithromycin and Chlamydophilia pneumonia infection on expansion of small abdominal aortic aneurysms—a prospective randomized double-blind trial. J Vasc Surg. 2009;50(1):23-9. [pmid: 19563951].
120 Vammen S, Lindholt JS, Ostergaard L, et al. Randomized double-blind controlled trial of roxithromycin for prevention of abdominal aortic aneurysm expansion. Br J Surg. 2001;88(8):1066-72. [pmid: 11488791].
121 Hogh A, Vammen S, Ostergaard L, et al. Intermittent roxithromycin for preventing progression of small abdominal aortic aneurysms: long-term results of a small clinical trial. Vasc Endovascular Surg. 2009;43(5):452-6. [pmid: 19640922].
122 Golledge J, Parr A, Boult M, et al. The outcome of endovascular repair of small abdominal aortic aneurysms. Ann Surg. 2007;245(2):326-33. [pmid: 17245188].
123 Peppelenbosch N, Buth J, Harris PL, et al. Diameter of abdominal aortic aneurysm and outcome of endovascular aneurysm repair: does size matter? A report from EUROSTAR. J Vasc Surg. 2004;39(2):288-97. [pmid: 14743127].
124 Vardulaki KA, Walker NM, Couto E, et al. Late results concerning feasibility and compliance from a randomized trial of ultrasonographic screening for abdominal aortic aneurysm. Br J Surg. 2002;89(7):861-4. [pmid: 12081734].
125 Lindholt JS, Juul S, Henneberg EW. High-risk and low-risk screening for abdominal aortic aneurysm both reduce aneurysm-related mortality. A stratified analysis from a single-centre randomised screening trial. Eur J Vasc Endovasc Surg. 2007;34(1):53-8. [pmid: 17331750].
126 McCarthy RJ, Shaw E, Whyman MR, et al. Recommendations for screening intervals for small aortic aneurysms. Br J Surg. 2003;90(7):821-6. [pmid: 12854107].
127 Wild JB, Stather PW, Biancari F, et al. A multicentre observational study of the outcomes of screening detected sub-aneurysmal aortic dilatation. Eur J Vasc Endovasc Surg. 2013;45(2):128-34. [pmid: 23273900].
128 Lesjak M, Boreland F, Lyle D, et al. Screening for abdominal aortic aneurysm: does it affect men's quality of life?. Aust J Prim Health. 2012;18(4):284-8. [pmid: 22951209].
129 Thompson SG, Ashton HA, Gao L, et al. Final follow-up of the Multicentre Aneurysm Screening Study (MASS) randomized trial of abdominal aortic aneurysm screening. Br J Surg. 2012;99(12):1649-56. [pmid: 23034729].
130 Hassen TA, Pearson S, Cowled PA, et al. Preoperative nutritional status predicts the severity of the systemic inflammatory response syndrome (SIRS) following major vascular surgery. Eur J Vasc Endovasc Surg. 2007;33(6):696-702. [pmid: 17276097].
131 Yusuf S, Wittes J, Probstfield J, et al. Analysis and interpretation of treatment effects in subgroups of patients in randomized clinical trials. JAMA. 1991;266(1):93-8. [pmid: 2046134].
132 Forbes JF, Brady AR, Brown LC, et al. Health service costs and quality of life for early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1656-60. [pmid: 9853437].
133 Stewart AL, Greenfield S, Hays RD, et al. Functional status and well-being of patients with chronic conditions. Results from the Medical Outcomes Study. JAMA. 1989;262(7):907-13. [pmid: 2754790].
134 Lindholt JS, Norman P. Screening for abdominal aortic aneurysm reduces overall mortality in men. A meta-analysis of the mid- and long-term effects of screening for abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2008;36(2):167-71. [pmid: 18485756].
135 Takagi H, Goto SN, Matsui M, et al. A further meta-analysis of population-based screening for abdominal aortic aneurysm. J Vasc Surg. 2010;52(4):1103-8. [pmid: 20541347].
136 Cosford PA, Leng GC. Screening for abdominal aortic aneurysm. Cochrane Database Syst Rev. 2007;(2):CD002945. [pmid: 17443519].
137 Lederle FA. Comment on “Screening for abdominal aortic aneurysm reduces overall mortality in men”. Eur J Vasc Endovasc Surg. 2008;36(5):620-1. [pmid: 18774311].
138 Takagi H, Niwa M, Mizuno Y, et al. The last judgment upon abdominal aortic aneurysm screening. Int J Cardiol. 2013;167(5):2331-2. [pmid: 23174171].
139 McPhee JT, Hill JS, Eslami MH. The impact of gender on presentation, therapy, and mortality of abdominal aortic aneurysm in the United States, 2001–2004. J Vasc Surg. 2007;45(5):891-9. [pmid: 17391899].
140 Heikkinen M, Salenius JP, Auvinen O. Ruptured abdominal aortic aneurysm in a well-defined geographic area. J Vasc Surg. 2002;36(2):291-6. [pmid: 12170209].
141 Forbes TL, Lawlor DK, DeRose G, et al. Gender differences in relative dilatation of abdominal aortic aneurysms. Ann Vasc Surg. 2006;20(5):564-8. [pmid: 16741651].
142 Acosta S, Ogren M, Bengtsson H, et al. Increasing incidence of ruptured abdominal aortic aneurysm: a population-based study. J Vasc Surg. 2006;44(2):237-43. [pmid: 16890847].
143 Sandgren T, Sonesson B, Ahlgren R, et al. The diameter of the common femoral artery in healthy human: influence of sex, age, and body size. J Vasc Surg. 1999;29(3):503-10. [pmid: 10069915].
144 Lederle FA, Johnson GR, Wilson SE, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. 1997;126(6):441-9. [pmid: 9072929].
145 Pirie K, Peto R, Reeves GK, et al. The 21st century hazards of smoking and benefits of stopping: a prospective study of one million women in the UK. Lancet. 2013;381(9861):133-41. [pmid: 23107252].
146 Svensjo S, Bjorck M, Wanhainen A. Current prevalence of abdominal aortic aneurysm in 70-year-old women. Br J Surg. 2013;100(3):367-72. [pmid: 23192439].
147 Linne A, Lindstrom D, Hultgren R. High prevalence of abdominal aortic aneurysms in brothers and sisters of patients despite a low prevalence in the population. J Vasc Surg. 2012;56(2):305-10. [pmid: 22425245].
148 Ogata T, MacKean GL, Cole CW, et al. The lifetime prevalence of abdominal aortic aneurysms among siblings of aneurysm patients is eightfold higher than among siblings of spouses: an analysis of 187 aneurysm families in Nova Scotia, Canada. J Vasc Surg. 2005;42(5):891-7. [pmid: 16275443].
149 Badger SA, O'Donnell ME, Boyd CS, et al. The low prevalence of abdominal aortic aneurysm in relatives in Northern Ireland. Eur J Vasc Endovasc Surg. 2007;34(2):163-8. [pmid: 17470405].
150 Mureebe L, Egorova N, Giacovelli JK, et al. National trends in the repair of ruptured abdominal aortic aneurysms. J Vasc Surg. 2008;48(5):1101-7. [pmid: 18771883].
151 Kung HC, Hoyert DL, Xu J, et al. Deaths: final data for 2005. Natl Vital Stat Rep. 2008;56(10):1-120. [pmid: 18512336].
152 Longo C, Upchurch GR Jr. Abdominal aortic aneurysm screening: recommendations and controversies. Vasc Endovascular Surg. 2005;39(3):213-9. [pmid: 15920649].
153 Hanly AM, Javad S, Anderson LP, et al. Screening for abdominal aortic aneurysms in cardiovascular patients. J Surg Res. 2006;132(1):52-5. [pmid: 16171823].
154 Badger SA, O'Donnell ME, Sharif MA, et al. Advantages and pitfalls of abdominal aortic aneurysm screening in high-risk patients. Vascular. 2008;16(421):201-6. [pmid: 18845100].
155 Mani K, Alund M, Bjorck M, et al. Screening for abdominal aortic aneurysm among patients referred to the vascular laboratory is cost-effective. Eur J Vasc Endovasc Surg. 2010;39(2):208-16. [pmid: 19942460].
156 Spencer CA, Jamrozik K, Norman PE, et al. The potential for a selective screening strategy for abdominal aortic aneurysm. J Med Screen. 2000;7(4):209-11. [pmid: 11202589].
157 Kent KC, Zwolak RM, Egorova NN, et al. Analysis of risk factors for abdominal aortic aneurysm in a cohort of more than 3 million individuals. J Vasc Surg. 2010;52(3):539-48. [pmid: 20630687].
158 Greco G, Egorova NN, Gelijns AC, et al. Development of a novel scoring tool for the identification of large ≥5 cm abdominal aortic aneurysms. Ann Surg. 2010;252(4):675-82. [pmid: 20881774].
159 Mell M, White JJ, Hill BB, et al. No increased mortality with early aortic aneurysm disease. J Vasc Surg. 2012;56(5):1246-51. [pmid: 22832264].
160 Robbins DA. Current modalities for abdominal aortic aneurysm repair: implications for nurses. J Vasc Nurs. 2010;28(4):136-46. [pmid: 21074116].
161 Altman DG, Vergouwe Y, Royston P, et al. Prognosis and prognostic research: validating a prognostic model. BMJ. 2009;338:b605. [pmid: 19477892].
162 Cook NR. Assessing the incremental role of novel and emerging risk factors. Curr Cardiovasc Risk Rep. 2010;4(2):112-9. [pmid: 20640227].
163 Mell MW, Hlatky MA, Shreibati JB, et al. Late diagnosis of abdominal aortic aneurysms substantiates underutilization of abdominal aortic aneurysm screening for Medicare beneficiaries. J Vasc Surg. 2013;57(6):1519-23. [pmid: 23414696].
164 Lederle FA. The rise and fall of abdominal aortic aneurysm. Circulation. 2011;124(10):1097-9. [pmid: 21900095].
165 Anjum A, von Allmen R, Greenhalgh R, et al. Explaining the decrease in mortality from abdominal aortic aneurysm rupture. Br J Surg. 2012;99(5):637-45. [pmid: 22473277].
166 Chun KC, Teng KY, Van Spyk EN, et al. Outcomes of an abdominal aortic aneurysm screening program. J Vac Surg. 2013;57(2):376-81. [pmid: 23141680].
167 Mastracci TM, Cina CS. Screening for abdominal aortic aneurysm in Canada: review and position statement of the Canadian Society for Vascular Surgery. J Vasc Surg. 2007;45(6):1268-76. [pmid: 17543696].
168 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 practice guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic). Circulation. 2005;113:e463-654. [pmid: 16549646].
169 Abramson BL, Hucknell V, Anand S, et al. 2005 Canadian Cardiovascular Society Consensus Conference: peripheral arterial disease—executive summary. Can J Cardiol. 2005;21:997-1006. [pmid: 16234879].
170 Ballard DJ, Filardo G, Fowkes G, et al. Surgery for small asymptomatic abdominal aortic aneurysms. Cochrane Database Syst Rev. 2008;(4):CD001835. [pmid: 18843626].
171 Rughani G, Robertson L, Clarke M. Medical treatment for small abdominal aortic aneurysms. Cochrane Database Syst Rev. 2012;(9):CD009536. [pmid: 22972146].
172 Hassan C, Pickhardt PJ, Laghi A, et al. Computed tomographic colonography to screen for colorectal cancer, extracolonic cancer, and aortic aneurysm: model simulation with cost-effectiveness analysis. Arch Intern Med. 2008;168(7):696-705. [pmid: 18413551].
173 Xiong T, Richardson M, Woodroffe R, et al. Incidental lesions found on CT colonography: their nature and frequency. Br J Radiol. 2005;78(925):22-9. [pmid: 15673525].
174 van Walraven C, Wong J, Morant K, et al. The influence of incidental abdominal aortic aneurysm monitoring on patient outcomes. J Vasc Surg. 2011;54(5):1290-7. [pmid: 21803526].
175 Gordon JR, Wahls T, Carlos RC, et al. Failure to recognize newly identified aortic dilations in a health care system with an advanced electronic medical record. Ann Intern Med. 2009;151(1):21-7. [pmid: 19581643].
176 Forsdahl SH, Solberg S, Singh K, et al. Abdominal aortic aneurysms, or a relatively large diameter of non-aneurysmal aortas, increase total and cardiovascular mortality: the Tromso study. Int J Epidemiol. 2010;39(1):225-32. [pmid: 19897467].
177 Freiberg MS, Arnold AM, Newman AB, et al. Abdominal aortic aneurysms, increasing infrarenal aortic diameter, and risk of total mortality and incident cardiovascular disease events: 10-year follow-up data from the Cardiovascular Health Study. Circulation. 2008;117(8):1010-7. [pmid: 18268154].
178 Grondal N, Sogaard R, Henneberg EW, et al. The Viborg Vascular (VIVA) screening trial of 65–74 year old men in the central region of Denmark: study protocol. Trials. 2010;11:67. [pmid: 20507582].
179 Twine CP, Williams IM. Systematic review and meta-analysis of the effects of statin therapy on abdominal aortic aneurysms. Br J Surg. 2011;98(3):346-53. [pmid: 21254006].