# Discussion

## Summary of Review Findings

Table 12 presents a summary of evidence for each KQ in order, which we briefly discuss next.

Table 12 Summary of Evidence

Key Question Comparison | # of studies (k); # of observations (n) | Design Aggregate internal validity | Major limitations | Consistency | Summary of findings and precision | EPC-rated strength of evidence | Applicability
Key Question 1 (benefits of 1-time screening) 1-time invitation screening vs. no screening (men age ≥65 y) | k=4; n=137,214 | 4 RCTs Fair- to good-quality | Only 1 trial (MASS) reported allocation concealment; no trials reported if providers were blinded. | High: 3 trials (MASS, Chichester, Viborg) consistently found statistically significant AAA-related mortality benefit; only 1 trial (Western Australian) did not find same, but baseline population was older, with lowest adherence to screening (62.5%) and highest control group surgery rate; all trials found no all-cause mortality benefit; pooled results had low heterogeneity for all-cause mortality and greater heterogeneity for AAA-related mortality. | 1-time invitation for AAA screening in men age ≥65 y reduces AAA rupture (RR, 0.27 [95% CI, 0.11 to 0.65]) at up to 10-y followup and AAA-related mortality (RR, 0.58 [95% CI, 0.39 to 0.88]) at up to 15-y followup. Screening has no effect on all-cause mortality up to 15 years in men (RR, 0.98 [95% CI, 0.97 to 1.00]). | Moderate | External validity limitations: Caucasian, male population, outside U.S. and studies did not report demographic, risk factor, or comorbidity characteristics of participants; therefore, difficult to assess if applicable to U.S. male population or how effect differs by subpopulation
Key Question 1a (subgroups) Subgroup effectiveness | Women: k=1; n=9,342 Older age: k=2; n=53,639 | RCTs (1 for women, 2 for age-specific subgroup analyses) Fair-quality | Women: did not report concealment, blinding, or differential followup Age subgroup analysis: internal validity limited by nature of post-hoc subgroup analysis. | Women: N/A (only 1 study) Age: low consistency because 1 subgroup analysis (Viborg) showed older (66–73 y) and younger age (64–65 y) groups have the same AAA-related mortality benefit from screening and 1 subgroup analysis (Western Australian) showed no benefit in either older (≥75 y) or younger (65–74 y) age groups; however, populations were different in these 2 trials. | 1-time AAA screening has no AAA-related or overall mortality benefit in women (based on few women studied), and no age-specific differences. | Insufficient | External validity: only 1 trial (Chichester) recruited any women (mostly Caucasian), so unclear if applicable to nonCaucasian women
Key Question 1b (screening approaches) High- vs. low-risk approach to screening | k=1; n=12,639 | 1 simulation from RCT N/A | Comorbidities ascertained from hospital discharge summaries (underascertainment), biasing against high-risk screening yield; comorbidity information collected post-randomization, thereby making this study a simulation. | N/A (only 1 study) | High- vs. low-risk approach: involves a tradeoff but absolute yield cannot be determined because of a lack of RCT-level or large generalizable cohort. | Insufficient | Concerns about internal validity make external validity unclear
Key Question 2 (benefits of repeated screening) | k=8; n=11,583 | 6 cohorts, 1 case-control, 1 patient-level meta-analysis Fair-quality | All were underpowered to detect AAA-related mortality difference and 3 studies reported no AAA-related mortality rates; therefore, growth rate/AAA incidence (intermediate outcomes) were the focus of results. Sparse demographic/risk factor information: only 2 studies reported this (both from ADAM subset). All studies had no adjustment for confounders. Only ADAM subset trial included women. | Too heterogeneous: rescreening interval frequently varied; no participant characteristics reported to understand if the populations were comparable; likely baseline characteristics of participants or imaging approaches were quite different across studies, as reflected by a wide variation in AAA incidence (2% to 88% initially normal aortas developed AAA ≥3 cm at 5-y followup). The patient-level meta-analysis reported a mean time from presentation to AAA rupture of 18.7 y. | Insufficient information for firm conclusions about yield of rescreening. | Low | Unclear: no population demographic/risk factor information for 5 out of 7 studies; 2 studies were in U.S.; most studies in men only
Key Question 2a (subgroups) Subgroup effectiveness | k=2; n=2,845 | 2 cohorts (both subsets from ADAM trial) Fair-quality | Studies did not report blinding or loss to followup. No adjustment for confounders was reported. | Inconsistent: both studies are subsets from same ADAM trial; smaller study found no association between risk factors tested and AAA incidence, larger study found associations using multilogistic regression with 3 factors (smoking, CAD, any atherosclerosis). | Conclusions about yield of rescreening by age, risk factor, or comorbidity limited by small number of events; conclusions about race and sex subgroups not possible because studies almost exclusively recruited white males; imprecise findings from the same study, perhaps due to power. | Low | VA populations, mostly men, so unclear if generalizable to greater U.S. population
Key Question 2b (screening interval | k=8; n=11,583 | 6 prospective cohorts; 1 case-control; 1 patient-level meta-analysis Poor-quality: studies highly heterogeneous, all studies underpowered to detect health outcomes | See details for KQ 2. | See details for KQ 2. | Insufficient information for conclusions about yield of rescreening by frequency. | Insufficient | See KQ 2 details
Key Question 3 (harms of screening) | Operative mortality and surgery: k=4; n=137,214 QOL: k=4; n=1,333 | 4 RCTs (operative mortality) Fair- to good-quality 5 observational studies (QOL) Poor-quality | Operative mortality/surgery: no major concerns of internal validity. QOL: small, pre-post studies, all self- administered questionnaires; no adjustment for confounders. | Operative mortality/surgery: consistent QOL: while heterogeneous designs, followup, and possibly populations (no baseline characteristics reported), overall studies consistently show no long-term QOL differences. | Invitation for screening is associated with more overall surgeries, more elective surgeries, and fewer emergent repairs up to 15-y followup; fewer emergency operations up to 10.1 y; lower 30-day operative mortality up to 10.1 y; no long-term difference in QOL, although screen-positive patients may have statistically lower short-term QOL at 6 weeks, which does not persist. | Operative mortality/ surgery: high QOL: low | Operative mortality/surgery: community surgeons, although outside U.S., likely applicable. QOL: unclear: no population demographic/risk factor information reported
Key Question 4 (benefits of treatment) Early open surgery vs. surveillance for small AAA | k=2; n=2,226 | 2 RCTs Good-quality | Both good-quality internal validity. UKSAT did not report AAA mortality or rupture as primary or secondary outcomes, so ascertainment method not described. | Consistent results in both trials. There were some differences in baseline population characteristics between the 2 trials; UKSAT had less HTN, CAD, and DM, but even with these differences, consistent results of no AAA-related mortality, rupture, or all-cause mortality benefit with early open surgery were seen in both trials. | Early surgery compared with surveillance for small AAA (4 to 5 cm) decreases AAA rupture (RR, 0.28 [95% CI, 0.13–0.62]) with attenuated benefit after 5 y, but does not alter all-cause or AAA-related mortality at 5-, 8-, or 12-y followup. | High | 1 trial was in the VA system, so possibly older population with more comorbidites, could influence surgical outcomes
Key Question 4 (benefits of treatment) EVAR vs. surveillance for small AAA | k=2; n=1,088 | 2 RCTs Fair-quality | Internal validity: industry sponsored, stopped early for futility so randomized groups were not similar for family history, sex, or DM. | Consistent results for all studies: no difference in all-cause or AAA-related mortality. | Early EVAR compared with surveillance for small AAA (4.0 to 5.0 or 5.4 cm) does not reduce all-cause mortality, AAA-related mortality, or AAA rupture. | Moderate | PIVOTAL participants had more comorbidities and higher risk than CAESAR and perhaps more comorbidities/higher risks than general population: family history of AAA (25%), higher CAD (55%), higher smoking (91%) proportion; therefore, may represent higher risk, especially with such high proportion with family history
Key Question 4 (benefits of treatment) Pharmacotherapy vs. placebo for small AAA | Antibiotics: k=3; n=371 Propranolol: k=1; n=552 | 5 RCTs Fair-quality | Small trials with primary outcome of AAA-growth; underpowered to detect health outcomes. | Inconsistent results: 4 trials each tested a different drug with heterogeneous baseline populations (different risks, sex). Some suggest decrease in AAA growth, others do not. | Short treatment with antibiotics (doxycycline, azithromycin, and roxithromycin) and beta-blocker (propranolol) does not appear to reduce AAA growth. Studies underpowered to conclude effect on health outcomes (AAA-related and all-cause mortality). | Low | Recruited from vascular center referrals, screening programs; difficult to make conclusions about generalizability because of single studies
Key Question 4a (subgroups) Subgroup effectiveness for treatment of small AAA | Open repair vs. surveillance: k=2; n=2,226 No subgroup results reported for EVAR or pharmacotherapy | 2 RCTs | Few women in ADAM; no results reported by smoking history, family history, comorbidity, or race in either RCT. | RCTs showed no all-cause mortality by age or AAA diameter. Only 1 trial with women. | At 5 y, no subgroup differences in all-cause mortality by age, sex, or AAA diameter. No evidence regarding smoking history, family history, comorbidity, or race subgroup differences. | | 1 trial (ADAM) is in VA population; largely older, male, multiple comorbid population compared with general population
Key Question 5 (harms of treatment) Early open surgery vs. surveillance for small AAA | Medical health outcomes/complications: k=2; n= 2,226 QOL: k=2; n=2,001 | 2 RCTs (health complications) Fair-quality 2 RCTs (QOL) Fair-quality | Small number of complications in each group. | Consistent complications and 30-day postoperative mortality. | Number of operations higher in early surgery group than surveillance group. Total major complications and MI more common in surveillance group compared than early surgery group, but 30-day postoperative mortality same in both groups. Health perception/overall health was improved in those undergoing early open surgery in first 1 to 2 y after discovery, but no difference in overall QOL between surgery and surveillance groups. | Moderate | ADAM trial was conducted in VA population, so question of applicability as high prevalence of coronary disease and overall sicker patients than general older male (>50 y) population
Key Question 5 (harms of treatment) Early EVAR vs. surveillance for small AAA | Health complications: k=4; n=2,440 QOL: k=1; n=339 | 2 RCTs, 2 registries (health complications) Fair-quality 1 RCT (QOL) Fair-quality | Industry sponsored, few harm events because RCTs were small trials, which were stopped prematurely because of futility. | Registries consistent in systemic complications. Higher 30-day postoperative mortality in EVAR reported in registries compared with PIVOTAL or CAESAR trials. | EVAR complications: systemic complications with EVAR approximately 15%. Endoleaks approximately 10%. Reintervention approximately 4%. Operative mortality does not appear to be different for early vs. late EVAR, suggesting that delay does not lead to poorer surgical outcomes. QOL better in early EVAR vs. surveillance group in the first 6 mo post-randomization, but no difference at 3 y. | Moderate | Registries likely closer to community practice complication rates and underlying population risk
Key Question 5 (harms of treatment) Pharmacotherapy vs. placebo for small AAA | Propranolol: k=2; n=606 Antibiotics: k=3; n=371 | 2 RCTs (propranolol) Fair-quality 3 RCTs (antibiotics) Poor-quality | All small trials | Propanol RCTs show a consistent lack of tolerability with no benefit. Antibiotic trials: heterogeneous; only 1 study for each antibiotic; making broad conclusions about antibiotics by qualitatively combining these studies not clinically appropriate. | Propranolol poorly tolerated, causing high withdrawal rate. Few adverse reactions reported in antibiotics studies but few events overall due to small number of participants. | Insufficient to low | Unclear

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal Aortic Aneurysm Detection and Management Study; CAD = coronary artery disease; CAESAR = Comparison of Surveillance vs. Aortic Endografting for Small Aneurysm Repair; CI = confidence interval; DM = diabetes mellitus; EPC = Evidence-based Practice Center; EVAR = endovascular aneurysm repair; HTN = hypertension; KQ = key question; MASS = Multicenter Aneurysm Screening Study; MI = myocardial infarction; N/A = not applicable; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early; QOL = quality of life; RCT = randomized, controlled trial; RR = relative risk; UKSAT = U.K. Small Aneurysm Trial; VA = Department of Veterans Affairs

## Direct Evidence on Mortality Benefit of Screening

Based on four large, population-based screening trials with up to 15 years of followup,13-16 our current meta-analysis confirms the conclusions of prior meta-analyses that there is convincing direct evidence that offering screening to men age 65 years and older decreases AAA-related mortality by approximately 50 percent over 13 to 15 years.134-136 Little controversy exists about the presence and magnitude of this AAA-related mortality benefit incurred with screening in men age 65 years and older, although the same is not true for all-cause mortality.134,137 While the most recent meta-analysis,138 which included the latest followup from MASS at 13.1 years,129 found a statistically significant reduction in all-cause mortality (fixed effect OR, 0.973 [95% CI, 0.950 to 0.997]), it combined mortality outcomes reported across followup times ranging from 3.6 to 15 years. Our meta-analysis used a random-effects model measuring risk ratio and found no statistically significant reduction in all-cause mortality; sensitivity analyses using ORs yielded similar point estimates to the most recent other meta-analysis.138

Expecting a meaningful reduction in all-cause mortality with one-time screening might be considered optimistic, given that AAA prevalence at age 65 years is around 4 percent, large AAA prevalence (>5 cm) is much less common (approximately 0.5%), and ruptures are rare (0.1% to 0.6% at 5 years). Even if the AAA-related mortality benefit from screening is close to a 50 percent risk reduction, a major effect on all-cause mortality might be unachievable since many large AAAs at risk for rupture will be found in older patients who have competing causes of mortality and comorbidities that limit their surgical candidacy.

A more detailed analysis of 7-year findings from MASS suggests that AAA-related mortality curves diverge at 1 year after screening, with life-years gained in the invited group increasing at a constant rate over the next 6 years.89 One-time screening in men age 65 years and older was very cost-effective (<$30,000 U.S. per life-year gained) at 7 years.

## Harms of Screening

With direct evidence of an overall and sustained AAA-related mortality benefit, specific screening-related harms are most relevant to patient-centered decisionmaking. Not surprisingly, screening leads to more elective AAA repairs but fewer AAA ruptures and less deaths due to emergency repairs. Making conclusions about psychological harms is more challenging; quality of life studies are small, largely (4 out of 5) case-control studies, and quite heterogeneous, with different study populations, scales, and followup periods. One study showed that the decreased quality of life in the screen-positive group (compared with the screen-negative group) at 6 weeks did not persist.13 Other studies showed prescreening versus postscreening quality of life to be lower or no different.89,104,105 One study showed that having small AAA followed by surveillance was associated with a lower quality of life compared with control.98

## Direct and Indirect Evidence for Screening in Subgroups

### Women

The Chichester trial provides the only direct evidence about the effect of AAA screening on health outcomes in women.25 Among 9,342 women ages 65 to 80 years, the AAA rupture rate in the invited and control groups was similarly low at 5 years (approximately 0.06% in both groups) and 10 years (0.19% and 0.21%, respectively). No sex-specific effect on AAA-related mortality was seen at 5 years. However, these findings are not definitive due to the relatively modest numbers of women studied and the sex-specific differences in the natural history of AAA demonstrated: AAA prevalence in women was six times rarer than in men (affecting power), and more AAA-related deaths occurred after age 80 years in women than in men (70% in women compared with <50% in men).25

A number of reports have found that women experience a consistent, three- to four-fold higher risk of AAA rupture than men.51,54,58,139 Three studies provide additional evidence that AAA rupture occurs at a smaller diameter in women than in men.54,58,140 In a cohort of 2,257 patients, including subjects from UKSAT and the U.K. Aneurysm Study, the mean AAA diameter preceding rupture was 6.0 cm (standard error, 1.4) in men compared with 5.0 cm (standard error, 0.8) in women (p=0.001).54 In a Canadian cohort (n=476), women were four times more likely to experience AAA rupture than men at diameters between 5.0 and 5.9 cm (95% CI, 1.2 to 13.0; p<0.001).58 The annual rupture rate at diameters larger than 6.0 cm was 14.1 percent for men and 22.3 percent for women. In a small Finnish study of 166 participants, 24 percent of women experienced AAA rupture at a diameter of smaller than 5.5 cm compared with 5 percent of men.140

A greater risk for large (≥5.0 cm) AAA rupture and for rupture at smaller diameters among women could reflect the greater proportional dilation of the normal female aorta to the 5.5 cm diameter threshold that triggers surgical intervention. A Canadian study of 129 subjects affirmed that AAAs of equal diameter represent a greater proportional dilation in women.141 Another factor suggested to contribute to greater risk for women is anatomical complexity associated with aneurysm repair142 due to smaller access vessels in women.48,143 One report suggests that EVAR delivery sheaths are relatively large for the female population.139

Data from a large ultrasound study found that female sex was significantly associated with smaller mean infrarenal aortic diameter (-0.14 cm) among those with normal aortic diameters after multivariable adjustment; absolute differences of 0.1 cm in infrarenal aortic diameter were equivalent to larger changes in other independent variables, such as age (29 years).144

From a population perspective, while the risk of AAA rupture is relatively higher in women than men, the absolute risk of AAA-related death in women, even in female smokers, is quite a bit lower than in men, largely due to the lower prevalence of AAA. In a prospective U.K. cohort study of 1.2 million women (median age, 55 years) followed for a period of 12 years, 330 current smokers (0.028%) and 164 female never-smokers (0.014%) died of AAA.145 A recent Swedish screening study in 5,140 women showed that the overall prevalence of AAA in women was 0.5 percent and was 0.8 percent and 2.1 percent, respectively, in female ever-smokers and current smokers.146

### Age

Age at initial screening could be important for understanding the risks and benefits demonstrated in the four major trials. The oldest men recruited to the trials ranged from an initial age of 73 to 80 years. The prevalence of AAA was higher in the two trials with older mean/median ages (Chichester and Western Australian) than in the two trials with younger enrollment ages (7% to 7.7% vs. 4%). Offering screening to an older population would theoretically result in greater benefit due to a higher yield of larger AAAs (>5 cm) that could be repaired to prevent rupture; however, only one of these trials demonstrated a reduction in AAA-related mortality with screening. Competing risks and limited suitability for surgical repair could offset the higher prevalence with older age.

Two trials reporting age-specific subgroups found no age-specific differences in the effects of screening on AAA-related or all-cause mortality.15,16 After 13 years, older men (ages 66 to 73 years) had a similar relative risk reduction for AAA-related mortality as younger men ages 64 to 65 years.15 After 3.6 years, no AAA-related mortality benefit was seen in the Western Australian trial, either overall or in age-specific subgroups (75 years and older vs. 65 to 74 years). While not suggesting age-specific differences, these data are limited by overall power, distribution and range of ages compared, and number of studies examining these subgroup issues.

### Family History

Family history remains one of the stronger individual risk factors after adjusting for age, sex, and smoking status (Table 13). In a large study (n=3,183 AAA cases; 15,943 controls) using Swedish population-based registries, researchers confirmed a doubling of AAA risk among those with one or more first-degree relatives with AAA, regardless of the sex of the index case or relative, and whether or not they also had comorbid conditions.46 Siblings appear to be a particularly relevant group, with a reported frequency of AAA of 11 percent,147 6 percent,148 and 4 percent149 in recent studies; female siblings appear to have much lower relative and absolute risk than male siblings. Among 10,012 female volunteers, the highest prevalence of screen-detected AAA was among women age 75 years and older (1.5%) and those with indications of heart disease (i.e., prior MI, coronary revascularization, or other cardiac surgery) (2.0%).12 Among 7,657 women age 65 years and older, the 464 women who were ever-smokers with heart disease (6%) had an AAA prevalence of 3.4 percent, while the few women who were ever-smokers with heart disease and a family history (n=31 [0.4% of women age 65 years and older]) had a prevalence of 6.6 percent.12 At least in women, these data suggest that family history alone would be insufficient to identify women to screen, as would smoking status. It is not clear how much family history would contribute to screening effectiveness in men beyond current recommendations.

Table 13 Odds Ratios of Risk Factors Associated With Developing AAA (Based on Adjusted Multivariate Analyses)

Factors associated with AAA | Any AAA ≥3 cm157 | Any AAA ≥4 cm48 | Any AAA ≥5 cm158
Male sex (vs. female sex) | 5.71 | NR | 7.70
Female sex (vs. male sex) | NR | 0.22 | NR
Age (vs. <55 y) | | 1.65
55–59 | 2.76 | | 3.20
60–64 | 5.35 | | 8.10
65–69 | 9.41 | | 13.20
70–74 | 14.46 | | 20.70
75–79 | 20.43 | | 32.0
≥80 | 28.37 | | 53.10
Hispanic/black/Asian (vs. white) | 0.69 to 0.72 | 0.49 to 0.91 | 0.70
Family history of AAA | 3.80 | 1.95 | 3.20
Smoking: years (<10 y, 10 to 35 y or >35 y) + packs per day (≤0.5, 0.5 to 1, >1) | 2.61 to 12.13 | 5.57 | 2.60 to 14.50
Smoking cessation (5 to 10 y, >10 y) | 0.42 to 0.87 | NR | 0.50 to 0.80
Diabetes | 0.75 | 0.54 | 0.70
CVD morbidity | 1.1 to 1.7 | 0.67 to 1.62 | 1.10 to 1.70

Abbreviations: AAA = abdominal aortic aneurysm; CVD = cardiovascular disease; NR = not reported.

### Comorbidity

A single screening trial (Viborg) reported AAA prevalence and AAA-related mortality outcomes in trial participants with and without six AAA-associated comorbidities.125 Longer-term93 or risk-factor specific125 analyses from this trial were not available at the time of the prior USPSTF recommendation.1 Based on the presence of one or more hospital discharge diagnoses (COPD, MI, hypertension, ischemic heart disease, peripheral artery disease, stroke, or transient ischemic attack), about one quarter (26.5%) of invited and control participants were considered high-risk at baseline, and these individuals had almost half (88/191) of all AAAs detected on screening. However, high-risk screening based on this approach would involve a tradeoff; it would screen 73 percent fewer patients but prevent only half of AAA deaths compared with a mass screening strategy. After a mean observation period of 5.9 years, AAA-related mortality was reduced by 8.4 deaths per 1,000 high-risk patients invited to screening (compared with no screening) and 3.7 deaths per 1,000 lower-risk patients. These data suggest a clearly superior benefit in those at higher risk status, presumably based on higher prevalence of AAA. Longer-term outcomes (13 years) from the same trial show a consistent relative risk reduction after screening in high-risk and lower-risk groups but a larger absolute AAA-mortality benefit in the high-risk group than the low-risk group. This study is limited in that the risk factor collection and analysis were done after trial randomization and risk-stratified comparisons represent subgroup analyses that do not conform to criteria for high-quality subgroup findings (i.e., those based on a significant treatment-by-group interaction or on subgroups that were balanced in the randomization process).93 Also, because comorbidities were derived from hospital discharge summaries, these high-risk participants were likely a select subgroup of the population, thereby creating bias against the projected yield from high-risk targeted screening.

### Risk Scoring

Although we found minimal direct evidence addressing subgroups in our systematic review, determining the most effective and efficient approaches to population-based AAA screening remains an important issue. In response to the 2005 USPSTF recommendation for a selective screening approach targeting male ever-smokers ages 65 to 75 years, concerns have been voiced about missed opportunities to prevent AAA rupture, particularly in women, younger nonsmoking men, and those with a family history of AAA. Specifically, critics note the substantial rupture rate and number of AAA-related deaths that occur in women (at least 33% of ruptured AAA hospitalizations and 41% of AAA-related deaths), while nonsmokers account for about 22% of AAA-related deaths.150-152 Perhaps a different high-risk approach (beyond smoking, age, and male sex) could identify a group with increased prevalence of AAA, and thereby be more effective and equally efficient. However, many higher-risk individuals have known comorbidities that could affect eligibility and/or complications associated with surgical treatment that could compromise the ability to attend surveillance. Thus, several studies have evaluated the yield and value of high-risk approaches, targeting those with existing or suspected cardiovascular conditions153,154 and/or COPD.125 As described above, investigators from the Viborg study determined that limiting screening to men with COPD and/or other CVD would reduce the number of individuals screened by 73 percent but miss more than half (52%) of AAAs in men ages 65 to 73 years.125 Screening in a cardiac clinic referral population resulted in a high (9.5%) prevalence of AAA (≥3 cm), all which were detected in patients older than age 60 years, who were four times more likely to be male and three times more likely to have ischemic heart disease.153 No consideration was given to whether those with AAA were suitable for surgical management. In a separate cardiology clinic setting, a similarly high prevalence (9.9%) of newly detected AAA was seen in male attendees ages 65 to 75 years, which was much higher than (5.4%) in men of the same age from the community.154 Ten percent of AAAs were large enough (≥5 cm) to consider surgery, but not all (one of four large AAAs) were eligible for open surgery or EVAR, and one of three patients with a repaired AAA had a complicated recovery due to comorbidity. In a retrospective study of individuals referred to a vascular laboratory, patients with screen-detected AAA were older (mean age, 72.8 years) and more likely to have competing comorbidities compared with those detected in screening trials; as a consequence, these patients were also less likely to undergo elective repair (21.5%) or full surveillance (48%), often due to poor health.155 Less than half (47.5%) were alive at the mean followup of 7.5 years (SD, 2.8), with more than half (56.8%) of deaths due to cardiac or cerebrovascular disease; one third (32.6%) due to cancer, COPD, or other nonvascular causes; 10.6 percent due to other vascular causes; and less than one in 10 (8.5%) related to the AAA (3.2% aortic rupture, 4.2% postoperative, 1.1% aortic dissection).

Using large-scale cohort data and/or population-based models, investigators have examined whether different targeted approaches could detect more clinically significant AAA with the same or better efficiency than the 2005 USPSTF recommended approach. One early effort developed and tested a novel multivariable risk factor score using data from the Western Australian screening trial. Results suggested that 50 percent of the male population would need to be screened to detect 75 percent of aneurysms measuring 4 cm or larger, while screening male ever-smokers would detect 87 percent of these aneurysms but require screening about two thirds of men.156 From this early study, authors concluded that mass screening remained preferable to selective screening, but they acknowledged that risk-prediction models based on better data might change this conclusion.

More recently, investigators developed and validated a novel scoring tool to predict prevalent AAA using demographic and medical history data from 3.1 million individuals who volunteered for community-based ultrasound screening.157 This study sample was different from the group currently recommended by the USPSTF for screening, as it was predominantly female (65%) and younger (20% age 55 years and younger, 34% ages 55 to 64 years). Prevalent AAA (infrarenal abdominal aortic diameter ≥3 cm) was detected in 0.77% of screened subjects (n=23,446), who were mainly male (79%), white (91%), and current or past smokers (80%). Among all age groups, the highest proportion of AAA detected was in those ages 65 to 74 years (44%), with more than half in persons outside the current USPSTF screening age range (i.e., 20% younger than age 65 years and 36% age 75 years and older). The majority (73%) of detected AAAs were small (3 to 4 cm), with a minority (17%) measuring from 4 to 5 cm, and just 10 percent considered large (≥5 cm); size distribution did not appear to vary with age. Based on multivariable analysis, male sex, age older than 60 years, and smoking at least one half pack per day for more than 10 years each independently increased the odds of any AAA five-fold (Table 13). Beyond confirming the strong and independent value of risk factors used to target screening (male sex, older age, smoking history) among those with an increased AAA prevalence, these data point out the contribution of family history of AAA and more detailed smoking history (pack-years). The analyses point out some protective factors that modify AAA risk (e.g., years since quitting smoking) or are associated with reduced AAA prevalence (e.g., nonwhite race/ethnicity, diet, exercise, diabetes). These risk factors were converted to scores based on their relative weights, which added up to a total AAA risk score ranging from 0 to 100.

The best predictive model for presence of AAA incorporated age, sex, detailed smoking history, race/ethnicity, cardiovascular risk factors and comorbidities, family history of AAA, diet, exercise, and body mass index. In the development subset of the cohort, this model discriminated well between those with and without AAA (area under the curve [AUC], 0.893). When tested in the remaining validation subset of the cohort, discrimination was diminished (AUC, 0.842) but calibration was very high (r^2^=0.98 for the association between predicted and observed probability of having an AAA, within each total risk score).

To further focus on detecting clinically significant AAA, the same investigators developed and validated a new model for predicting the presence of large AAA (≥5 cm) using a similar study sample from the same voluntary screening population, but also including those age 85 years and older.158 There were 2,430 individuals (0.08% of all persons screened) with an AAA of 5 cm or larger; 84.4 percent of those with large AAAs were male and 83% were ever-smokers. Few (18%) large aneurysms occurred in those younger than age 65 years, with the remainder evenly divided between those ages 65 to 74 years (41%) and age 75 years and older (41%). About one third (36.3%) of the large AAAs in this cohort occurred in the 207,493 male ever-smokers ages 65 to 75 years who would be recommended for screening using the 2005 USPSTF recommendation. As Table 13 illustrates, some factors (such as male sex and older age) are even more strongly associated with large AAA than with any AAA.

In order to compare the potential effect of various risk-based screening strategies in the United States, these same investigators modified their initial risk prediction models to include only risk factors available in National Health and Nutrition Examination Survey data to estimate the prevalence of any AAA or large AAA in the U.S. population.157,158 Using these data on estimated prevalence, the authors then simulated the yield and screening requirements of various risk-based screening strategies.

These simulations suggest that the 2005 USPSTF approach is reasonably effective and relatively efficient for detecting any AAA or large AAA compared with universal screening. Current screening data also support the USPSTF approach, with recent studies reporting that more than 80 percent of AAAs were found in ever-smokers.11,159,160 The current USPSTF recommendation is estimated to detect 29.5 percent of an estimated 1.1 million prevalent AAAs in the U.S. population, requiring 20 screenings per AAA found. For any large AAA, the simulated yield of the 2005 USPSTF approach would detect 33.7 percent of an estimated 120,810 large AAAs, requiring 168 screenings per large AAA detected. The simulated yield and requirements of different screening approaches based on risk scores could potentially detect more AAAs of any size than the USPSTF strategy (from 42.3% to 66.5% of estimated prevalent AAAs) at about the same efficiency, or could be more effective at detecting large AAAs (from 45.8% to 84.2% of estimated large AAAs) at increased efficiency (67 to 156 screenings per AAA detected). However, in these simulated strategies, the age distribution of screen-detected large AAA also tends to shift to the older age groups (>75 years). As has been demonstrated in other studies,155 cases detected in older or more ill individuals may be less likely to be eligible for surgical repair or may have worse perioperative morbidity/mortality and long-term survival than cases detected in large screening trials, thus potentially reducing the expected health benefit from these types of risk-based screening strategies.

While intriguing, these findings require some caveats. First and foremost, by simulating yield, these data cannot represent health outcomes due to incompletely capturing issues around treatment eligibility and harms. Second, these risk models are both derived from the same cohort and are validated only internally; either would require external validation in a completely separate cohort before clinical application could be considered.161 This is particularly true since the internally-derived risk factor profile was used to project the prevalence of AAA in the general population, and thus the model may be more optimistic than if it were assessed against empirically documented AAAs. Also, as the development and validation cohort was based on individuals who were primarily self-referred, the self-reported risk factors in this cohort may not be comparable with the U.S. population to whom it was applied. Third, the modified risk model used in the simulations excluded some strong contributors to the risk score in the original model, particularly family history of AAA. Although the AUC of the modified model was reported to be almost as good as the initial model, AUC is an insensitive measure of model differences since it is based solely on rankings.162 Authors did not report other comparisons of the two models. Finally, all of these modeled data are cross-sectional and presume that prevalent AAA in individuals older than the USPSTF screening range are undetected and equally important to detect (i.e., as amenable to preventive benefit from clinical intervention) as those in younger adults; similarly, the simulations presume that prevalent AAAs in those younger than age 65 years are important to detect before recommended screening would commence at age 65 years (or are in groups who are never recommended to receive AAA screening).

Nonetheless, these interesting data should encourage further investigation and consideration of more targeted risk strategies for detecting and treating AAA early to prevent AAA-related mortality and morbidity. In particular, a risk prediction emphasis on detecting larger aneurysms could address in part the important issue of potential overdiagnosis in older adults (who might have smaller aneurysms that would never progress enough to require intervention). Further research in this area should be a high priority since these studies suggest important, feasible strategies that could improve AAA screening recommendations overall and for underserved groups, including women, younger high-risk adults, and older healthy adults. Moreover, it would be extremely useful to have more robust models for assessing the value and requirements of risk-based screening approaches that address various surveillance and treatment approaches, competing risks and contraindications to treatment, and rescreening across a broader population group.

### Recent Decline in AAA Prevalence

Recent epidemiologic evidence from population-based screening programs in Europe and New Zealand demonstrate a substantial decline in AAA prevalence in men age 65 years and older over the past two decades, with current AAA prevalence reported at 1.5 to 1.7 percent (AAA ≥3cm).11,17-19 There have not been any similar epidemiologic reports from the United States, likely because screening uptake is low, which makes it difficult to estimate the true prevalence in the population of men age 65 years and older.163 Declining smoking rates could largely account for this observed decline,164,165 though there is likely also a contribution from declining atherosclerotic disease due to aggressive management of hypertension and hyperlipidemia with statins.11,146 This decline in prevalence must be considered carefully in estimating the yield from mass versus targeted screening approaches and certainly favors a more targeted approach (i.e., ever-smokers) similar to that which the USPSTF previously recommended. One recent retrospective chart review from the Northern California VA (2007 to 2011) of male veteran ever-smokers ages 65 to 75 years with a mean age of 71.5 years (N=9,751) reported a prevalence of AAA of 3 cm or larger of 7.1 percent, but there were more smaller aneurysms detected than previously reported (only 6.6% of AAAs detected were ≥5.5 cm compared with 12% in MASS).166 This suggests that even if the overall prevalence of AAA were declining in the United States as it is in other countries, the risk of AAA in ever-smokers may continue to remain high, with a shift toward smaller aneurysms. No single risk factor other than age, sex, or smoking history is as strong of a predictor of AAA, thereby making a multiple risk factor approach appealing once a validated risk score is available.

## National/International Guidelines

Differing international guidelines reflect variations in the interpretation of direct and indirect evidence on AAA screening in subgroups (Appendix J). While most guidelines have some consensus on the starting age of 65 years for one-time screening, the upper age limit is unspecified in most recommendations. In those specifying an upper age limit, most recommend stopping at age 75 years (USPSTF, American College of Cardiology [ACC], Canadian Society for Vascular Surgery), while one organization recommends stopping at age 85 years (Society for Vascular Surgery).1,24,167-169 The USPSTF 2005^1^and ACC168 guidelines specify smoking as a risk factor for targeted screening, while others incorporate family history of AAA into the definition of a target population.24,168,169 Several guidelines recommend screening in high-risk women, where high-risk is defined as having CVD risk factors and/or a family history of AAA,24,167,169 whereas other organizations, such as the ACC and USPSTF, do not recommend screening women.1,168 Guidance on the screening interval for ultrasound surveillance is generally based on AAA size on initial screening but varies widely; generally, larger aneurysms (>4.0 to 4.5 cm) are rechecked every 6 to 12 months, with 1 to 3 years for smaller aneurysms.1,24,167-169

## Treatment Studies for Small AAA

The AAA-related mortality benefit in screening trials was achieved through immediately referring large AAAs (>5.5 cm) for appropriate surgical treatment, while monitoring smaller aneurysms with repeat ultrasounds every 3 to 12 months followed by surgical referral for rapid growth or reaching large AAA size over about 5 years. An important opportunity for increasing the expected net benefit from current screening programs could come from potential improvements in the surveillance and surgical management of small AAAs, particularly since these are much more common than larger aneurysms.

Two major, good-quality RCTs provide robust assessment of the benefits and harms of early open surgery compared with surveillance of small AAA in populations applicable to clinical practice.106,102 There is strong evidence that early open surgery compared with surveillance does not reduce all-cause or AAA-related mortality, although it reduces 5-year risk of rupture (18 fewer AAA ruptures per 1,000 individuals with small AAA treated with early open surgery rather than surveillance). Early open surgery resulted in 50 percent more surgical procedures (313 more surgeries per 1,000 persons with small AAA). There was no difference in postoperative or 30-day operative mortality among those undergoing early versus delayed open surgical repair, but those undergoing delayed surgical repair may have slightly more total complications (45 per 1,000 persons undergoing delayed rather than immediate repair) or major complications (2 per 1,000 persons), particularly postoperative MI. Early surgery generally does not improve patients' overall quality of life, although health perception may be improved in the first 1 to 2 years. In one trial, early open surgery increased the risk of impotence over the first several years.

Two moderate-sized, fair-quality trials assessed the benefits and harms of early EVAR versus surveillance in patients with small AAA who are applicable to clinical practice.113,115 These two trials are limited by relatively short-term followup and a small number of events due to early stopping for reaching futility (i.e., the statistical impossibility of treatment showing a benefit). Although point estimates are imprecise, available data suggest no difference in the risk of all-cause mortality, AAA-related mortality, or AAA rupture with surveillance instead of early EVAR. Those in the surveillance arm were able to avoid an estimated 549 surgeries (range, 484 to 582) per 1,000 individuals with small AAA managed through surveillance rather than early EVAR, and surgical outcomes (30-day operative mortality or complications) for delayed surgery after surveillance showed no difference when compared with early EVAR. Early EVAR was associated with improved quality of life, at least over the short term, but may also result in more short- and longer-term device-related endoleaks. Two moderately-sized, fair-quality registry studies found two to three times higher 30-day operative mortality with EVAR than in these trials (1.1% to 1.6% vs. ≤0.5%), suggesting further caution in treating small aneurysms with early EVAR based on available evidence.

Pharmacological treatment may minimize aneurysm progression, but current evidence is too limited in quality and in numbers of patients and types of treatments studied to make many firm conclusions. There is adequate evidence only for propranolol, which has little to no effect on AAA growth rate, all-cause mortality, AAA-related mortality, and rupture. It is poorly tolerated, with significantly increased adverse effects and frequent discontinuation of treatment. In contrast, studies of antibiotics generally do not show many adverse effects, but these studies cannot demonstrate a clear finding on AAA growth rate, all-cause mortality, AAA-related mortality, and rupture because of heterogeneous patient populations, short-term administration (4 to 15 weeks), differences in outcome reporting, and small numbers of events.

Generally, current evidence reviewed here or by others does not support the treatment of small AAA with early open surgery, early EVAR,170 or pharmacotherapy.171 In our review, patients identified with small AAA appeared to experience some decline in quality of life during followup, with any differences due to management strategies primarily limited to short-term effects favoring intervention. It is possible that patient reassurance may alleviate concerns leading to decreased quality of life, but this was beyond the scope of our review.

## Rescreening

There remains controversy regarding the yield of rescreening after a normal initial screening. Some authors have used incident AAA and growth rates to advocate rescreening at 2-, 4-, or 5-year intervals.98-100 Six of our included studies96,98-102 report AAA growth in normal aortas (2.5 to 3 cm); the largest study99 (4,308 participants) and one other included study98 showed a growth rate of 1.7 to 1.8 mm per year for a median 4- to 5-year followup in those with aortas measuring 2.5 to 2.9 cm. Five trials show a rare AAA-related mortality (0% to 0.56%) at 5- to 10-year followup with various rescreening intervals in those with aortas measuring 2.5 to 2.9 cm on initial scan.96,97,99,101,102 A larger analysis from the ADAM study101 showed that current smoking, coronary disease, and any atherosclerosis were predictive of incident AAA at the 4-year rescreening interval, but in this study of over 5,000 veterans, AAA-related mortality was zero. Again, many of these newly detected (incident) AAAs (incident rate, 2.2 [95% CI, 1.7 to 2.8] at 4 years) will be small (only 3 of 58 new AAAs were 4 to 4.9 cm and none were ≥5 cm). While it may be tempting to use these growth rates and incident AAAs to make decisions about rescreening frequency, most incident AAAs are small and may not have clinical consequence.

## Incidental AAA on Computed Tomography Examination

Incidental AAAs are aneurysms identified when the abdomen is imaged for other reasons, such as colorectal cancer screening.172 One systematic review of 17 studies found that 0.9 percent of subjects undergoing computed tomography (CT) colonography screening had a finding of incidental AAA.173 We did not locate any studies that followed subjects with negative incidental AAA findings on CT scan to determine the negative predictive value of no incidental finding.

Two studies, however, report that findings of positive incidental AAA are not well documented or followed up.174,175 In a retrospective cohort of 191 patients with incidental AAA found by ultrasound, magnetic resonance imaging, or CT with a median observation time of 4.4 years, 29.3 percent of subjects had no followup imaging of their aneurysm,174 and only 26 percent of those who were inpatients had discharge summaries mentioning the finding. Another retrospective cohort found that in 61.4 percent of 83 incidental AAAs, there was no documentation that the primary care physician was aware of the results in the electronic medical record within 3 months of the CT scan.175 Using a multivariable regression model, the study found that subjects with incidental AAA not receiving radiological monitoring for 1 year were significantly more likely to die (HR, 2.99) compared with subjects receiving recommended radiological monitoring; this finding was independent of age, baseline AAA diameter, care setting, and patient morbidity.

Based on these limited data, previous CT scanning could not be presumed to substitute for recommended AAA screening, since it is not clear how completely CT scans for other purposes identify incidental AAA. Further, when incidental AAAs are identified, they may not be as effectively surveyed as those detected in a structured screening program.

## Limitations Due to Our Approach

Our approach might be limited by several factors, including a reliance on English-language literature only, a requirement for RCTs or large cohort studies for screening and treatment benefits, and a requirement that studies meet the USPSTF's fair- or good-quality criteria.86 Similarly, as the focus of this systematic review was to update a previous USPSTF review,44 some issues, such as risk assessment, incidental AAA detection on CT screening for other purposes, and possible sex differences in the risk of rupture at a specific aortic diameter, were addressed as part of the introduction or discussion but not systematically reviewed.

## Limitations Due to the Evidence Base

### Population Screening Issues

The four large population-based screening trials, while robust in numbers, almost exclusively represent a population of older Caucasian men. There is no direct evidence examining AAA-related mortality benefit in any subpopulations other than women and older men; the single screening study in women was underpowered to detect differences in health outcomes. While populations of smokers, those with a family history of AAA, and those with CVD represent groups with higher risk of AAA, there is no direct evidence examining the health outcomes resulting from screening these populations. Likewise, there is no direct evidence about high- and low-risk approaches to screening.

### Repeat Screening Trials

The cohort studies examining AAA growth and mortality were not adequately powered to detect differences in health outcomes afforded by screening, and the body of rescreening literature is heterogeneous, with various surveillance intervals and treatment protocols.

### Harms of Screening

The literature examining quality of life and psychological harms of screening comprised a heterogeneous group of cohort, case-control, and observational studies derived from subsets of larger trials using different instruments and followup periods, making long-term harms difficult to quantify. There were no studies examining AAA-specific quality of life instruments.

### Treatment Studies

Inconsistent definitions of treatment-related morbidity across surgical treatment studies complicate their interpretation and limit their use in syntheses. Most nonsurgical treatment studies were conducted using relatively small, short-term studies of selected populations, with limited variability (or undocumented variability) in important potential effect modifiers (such as smoking, sex, age, and comorbidity). Women were underrepresented in the ADAM, CAESAR, and pharmacotherapy trials. No RCTs examined the benefits of several potentially promising pharmacologic treatments for small AAA, such as statins, ACE inhibitors, or better tolerated beta-blockers. Few treatment studies are designed to adequately assess health outcomes. Focus on AAA growth rate could be a useful intermediate outcome if future studies more consistently report AAA growth using the same metrics at the same time points and with some quality assurance of measurements, in addition to other important bias minimization tools, such as blinding of outcomes assessors.

## Emerging Issues/Next Steps

### Screening

Because the etiology of AAA is not fully understood, independent risk factors for AAA development as well as factors influencing AAA growth remain to be defined, including the role of genetic markers in AAA development. While a few hypotheses have been posited to explain AAA growth, none has been confirmed by clinical studies designed to address these hypotheses. Investigation of additional mechanisms and possible interactions among the mechanisms may be warranted. Targeted screening approaches continue to be an area of debate in the literature; accurate identification of high-risk populations who could survive and benefit from surgery remains a challenge.

There is some emerging interest in exploring the potential effects of AAA screening on CVD mortality by identifying those at increased risk for atherosclerotic coronary disease and ischemic stroke.176,177 MASS reported ischemic heart disease–related deaths in screened and unscreened groups, showing no difference at 13 years, thereby questioning whether AAA screening has such effects.129

### Treatment

There is a need to further explore alternative strategies to reduce AAA growth, such as antibiotics, statins, or other novel pharmacologic agents. Interventions to address modifiable risk factors (particularly smoking) may be worth considering in reducing AAA growth. Effective smoking cessation strategies may improve the care of patients with small AAA.

## Future Research

### Screening

The yield of targeted screening approaches in populations with CVD, peripheral vascular disease, and family history of AAA, as well as the yield of rescreening, will continue to be debated using simulated models until large screening RCTs with sufficient power and a decade or more of followup can confirm such benefit. In the absence of such a trial, a risk-scoring approach with associated health outcomes will need to be developed and validated in the U.S. population.

There is one in-progress RCT on screening: the Viborg Vascular screening trial, which is evaluating the effectiveness of combined screening for AAA (ultrasound), peripheral artery disease (ankle–brachial index), and hypertension in 50,000 men ages 65 to 74 years recruited from a central Denmark national registry (Appendix C).178 Enrollment began in October 2008 and ended in 2010, with planned followup at 3.5, 10, and 15 years. For those who screen positive for AAA or peripheral artery disease, trained nurses will provide advice on exercise, low-fat diet, and smoking cessation, and medical management with statins and aspirin will be initiated. Annual surveillance for AAA and peripheral artery disease will be provided, and those with AAAs measuring 5.0 cm or larger will be referred for vascular surgery. The trial's primary outcome is all-cause mortality ascertained from national death registries; secondary outcomes include cardiovascular mortality, AAA-related mortality, AAA prevalence and progression, health-related quality of life, and cost-effectiveness.

Finally, there is one prospective cohort screening trial in Oslo recruiting 1,500 men age 65 years, with a primary outcome of AAA prevalence/incidence and a secondary outcome of peripheral artery disease incidence in participants with AAA over an 18-year followup period, with an estimated completion date of 2029 (Appendix C).

### Treatment

More efforts are needed to examine the effect of pharmacotherapy for the treatment of small AAA in large, high-quality RCTs with longer followup and measurement of health outcomes (AAA-related and all-cause mortality). While a number of observational studies have demonstrated the effect of statins on growth,179 RCTs measuring health outcomes are needed.

Currently, there are seven ongoing RCTs examining pharmacotherapy effects on small AAA (3 to 5 or 5.5 cm): two small angiotensin receptor blocker trials measuring growth or AAA incidence, one ACE inhibitor trial, two small trials of anti-inflammatory medications, and two doxycycline trials (Appendix C). The primary outcome in most trials is aneurysmal growth. These trials are all small and underpowered to detect differences in health outcomes.

## Conclusions

The following new literature has been published since the last systematic review performed to support the 2005 USPSTF recommendation:44 longer-term followup from four population-based RCTs confirming the AAA-related mortality benefit afforded from screening; one new simulation study examining high-risk versus low-risk targeted approaches;125 and a few internally-validated simulation models assessing the effectiveness and efficiency of risk-scoring systems. Treatment literature in this interim period has confirmed the lack of benefit from open surgery or EVAR for small AAA compared with surveillance and no evidence of benefit of pharmacotherapy for small AAA, thereby making the detection of small AAA more problematic.