# Methods

## Scope and Purpose

This systematic review will provide updated evidence regarding the effectiveness of one-time and repeated screening for AAA, the associated harms of screening, and the benefits and harms of available treatments for small AAA (3.0 to 5.0 cm) identified through screening. The USPSTF will use this review to update its 2005 recommendation for primary care practices. This review included all trials from the previous review that met current inclusion/exclusion criteria, as well as newly identified studies.84

## Key Questions and Analytic Framework

Using the USPSTF's methods (detailed in Appendix A),85 we developed an analytic framework (Figure 1) and five key questions (KQs).

Figure 1 Analytic Framework

Abbreviations: AAA = abdominal aortic aneurysm; EVAR = endovascular aneurysm repair; OPEN = open abdominal aortic aneurysm repair; QOL = quality of life.

Figure 1 is an analytic framework that depicts the five Key Questions described in the Methods section of the report. In general, the figure illustrates how screening for AAA in asymptomatic adults age 50 years and older may reduce AAA-specific and all-cause mortality, as well as AAA rupture rates. In addion, it examines the effectiveness of rescreening patients who were previously found to be negative for AAA and the benefits and harms of treating small AAA (3.0 to 5.4 cm).

The KQs include:

1. What is the effect of one-time AAA screening on health outcomes in an asymptomatic population age 50 years and older?
  a. Does the effect of one-time screening vary between men and women, smokers and nonsmokers, older (≥65 years) and younger (<65 years) patients, patients with and without a family history of AAA, and patients of different races/ethnicities?
  b. Does the effect of one-time screening vary between different screening approaches?
2. What is the effect of rescreening for AAA on health outcomes or AAA incidence in a previously screened, asymptomatic population without AAA?
  a. Does the effect of rescreening vary between men and women, sizes of AAA, smokers and nonsmokers, older (≥65 years) and younger (<65 years) patients, patients with and without a family history of AAA, and patients of different races/ethnicities?
  b. Does the effect of rescreening vary between different time intervals?
3. What are the harms associated with one-time and repeated AAA screening?
4. What is the effect of pharmacotherapy versus placebo or surgery (open and EVAR) versus surveillance on treatment-relevant intermediate health outcomes in an asymptomatic population with small AAA (3.0 to 5.4 cm) identified by screening?
  a. Does the effect of pharmacotherapy, surgery, and surveillance differ between men and women, smaller (3.0 to 4.0 cm) and larger aneurysms (4.1 to 5.4 cm), smokers and nonsmokers, older (≥65 years) and younger patients (<65 years), patients with and without a family history of AAA, patients with and without diabetes, patients with and without chronic obstructive pulmonary disease (COPD), or patients of different races/ethnicities?
5. What harms are associated with pharmacotherapy, EVAR and open surgery, and surveillance in an asymptomatic population with small AAA (3.0 to 5.4 cm) identified by screening?

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion in the current review, we performed a comprehensive search of MEDLINE, the Database of Abstracts of Reviews of Effects, and the Cochrane Collaboration Registry of Controlled Trials for studies published between January 2004 and June 1, 2012. A bridge search was conducted through January 2013. We worked with a medical librarian to develop our search strategy (Appendix B). All searches were limited to articles published in the English language. The literature search results were managed using version 12.0 of Reference Manager® (Thomason Reuters, New York, NY).

To ensure the comprehensiveness of our retrieval strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before the timeframe of or not identified in our literature searches. In addition, we obtained references from outside experts. We also searched federal agency trial registries for ongoing and/or unpublished trials (Appendix C). We also used news and table-of-contents alerts from Google (Google, Inc., Mountain View, CA), and ScienceDirect (Elsevier, Maryland Heights, MO) to help us identify potentially eligible trials that were published between bridge searches.

## Study Selection

Two reviewers independently reviewed the title and abstracts of all identified articles to determine if the study met the inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A). Two reviewers then independently evaluated the full-text article(s) of all potentially included studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer if necessary. Excluded studies and reasons for exclusion are listed in Appendix D.

We developed an a priori set of criteria for inclusion and exclusion of studies based on our understanding of the literature (Appendix A Table 1). For KQs 1 and 2, examining the effectiveness of one-time and repeated screening, we considered RCTs and large cohort studies (n ≥1,000) of asymptomatic adult populations. For KQ 4, examining the effectiveness of treating small AAA, we considered only RCTs of asymptomatic adult populations with AAAs identified as small (3.0 to 5.4 cm). For KQs 3 and 5, examining the harms of screening for AAA and of treating small AAA, we were more inclusive and considered RCTs, observational and case-control studies, and registry data related to surgical harms. For KQ 5, we considered only populations of adults with asymptomatic small aneurysms. For all KQs, the only screening modality that we considered was ultrasound. We did not consider physical examinations due to literature reporting unfavorable sensitivity and specificity of this diagnostic method.70 Further, we did not consider CT or magnetic resonance imaging screening, as these modalities are not readily available in primary care. For KQ 2, we accepted targeted screening defined as screening based on one or more patient risk factors or screening based on prediction/prognostic modeling. For KQs related to the treatment of small AAA, we considered surgical (open or EVAR) or pharmacotherapy interventions (statins, ACE inhibitors, beta-blockers, or antibiotics) compared with surveillance, usual care, or placebo. We limited included studies to those that were deemed good- or fair-quality by the USPSTF quality rating standards86 and those published in English. Studies of poor quality and those not published in English were excluded. The outcomes that were reviewed are fully listed in Appendix A Table 1.

## Quality Assessment of Evidence

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF86 and supplemented with the National Institute for Health and Clinical Excellence methodology checklists for observational studies.87 Disagreements in quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor.

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., little to no statistically significant differences between groups in baseline demographics and characteristics), low attrition (≥90% of participants had followup data, with <10 percentage-point difference in loss to followup between groups), and used conservative data substitution methods if missing data were inferred. Trials were downgraded to fair if they were unable to meet the majority of the good-quality criteria. Trials were rated as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there were any other “fatal” flaws that seriously affected internal validity, as agreed upon by two independent investigators. Poor-quality studies were excluded from the review (Appendix D).

Good-quality observational studies had an unbiased selection of the nonexposed cohort and adequate ascertainment of exposure. These studies addressed a population without the outcome of interest at the beginning of the study, and they had reliable outcome measures, blinded assessment, low attrition, adjustment for potential confounders, and no other important threats to internal validity. Observational studies were downgraded to fair if they were unable to meet the majority of good-quality criteria. Poor-quality observational studies had multiple threats to internal validity and were excluded from the review.

## Data Extraction

One reviewer extracted data from all included studies rated as fair- or good-quality into a standard evidence table and a second reviewer checked the data for accuracy. Elements abstracted included population characteristics (e.g., baseline demographics, body mass index, concurrent conditions, family history of AAA, smoking status, and CVD risk factors), study design (e.g., recruitment procedures, inclusion/exclusion criteria, followup, and population adherence), intervention characteristics, and postscreening management, as well as health outcomes.

Health outcomes included the number of participants experiencing an event and incidence rates. For KQs 1, 2, and 3 (efficacy and harms of screening), we abstracted the reported incidence and prevalence of AAA, incidence of ruptured aneurysms, and mortality (all-cause, AAA-related, and operative). In addition, we extracted information on the number and circumstance (i.e., emergency or elective) of surgical interventions reported in each study and any adverse events related to screening (e.g., changes in quality of life, anxiety) that were reported. For KQs 4 and 5 (efficacy and harms related to treating small AAA), we abstracted data related to the dose and duration of the pharmaceutical intervention, surgical details (if reported), AAA growth rate, the number and circumstance (i.e., emergency or elective) of surgical interventions, incidence of aneurysm rupture, and mortality (all-cause, AAA-related, and operative). For adverse events, we extracted all that were reported, but specifically looked for incidence of reinterventions, endoleaks, device migration, conversion to open surgery, and readmission to the hospital within 30 days of surgery.

## Data Synthesis and Analysis

We synthesized data separately for each KQ. Specifically, we qualitatively summarized each of the included studies regarding study design and setting, internal validity and major factors threatening the internal validity, and important characteristics about patients and interventions.

### Data Synthesis for KQ 1 (Benefits of Screening for AAA)

We examined all-cause mortality, AAA-related mortality, rupture, and emergent repairs for ruptures for the comparison of screening versus no screening. We used the DerSimonian and Laird random effects model as the primary analysis to pool trials.88 All statistical testing was two-sided and 0.05 was considered significant. We analyzed risk ratios for all outcomes. We examined statistical heterogeneity across trials with the I^2^ statistic and chi-square test of heterogeneity.

We undertook the following sensitivity analyses to check the robustness of results:

- We conducted fixed-effects meta-analyses for trials, and we qualitatively compared the results between the fixed- and random-effects model.
- We conducted random-effects meta-analyses of trials reporting HRs for all-cause mortality, AAA-related mortality, and rupture, and we qualitatively compared the pooled estimates using HRs versus risk ratios.
- We conducted meta-analyses of trials reporting AAA-related mortality using the Peto odds ratio (OR) method to address rare events and to see if there were any important changes in significance compared with the DerSimonian and Laird models.
- We examined long-term followup for all-cause mortality, AAA-related mortality, and AAA rupture using the outcome data reported at the latest followup.

We also applied funnel plots to examine publication bias for the main health outcomes, including all-cause mortality, AAA-related mortality, and AAA rupture.

### Data Synthesis for KQ 2 (Benefits of Rescreening for AAA)

Because of substantial differences in patient population, length of followup, and outcomes reported, we were unable to pool studies. We thus qualitatively summarized data and reported outcomes, including incidence of AAA, AAA ruptures, AAA-related mortality, and all-cause mortality.

### Data Synthesis for KQ 3 (Harms of One-Time Screening and Rescreening for AAA)

For the comparison of screening versus no screening, we examined 30-day mortality, 30-day mortality after elective surgery, 30-day mortality after emergency surgery, and overall number of operations, elective operations, and emergency operations. We used the DerSimonian and Laird random-effects model as the primary analysis to pool trials.88 All statistical testing was two-sided and 0.05 was considered significant. We analyzed risk ratios for all outcomes. We examined heterogeneity across trials with the I^2^ statistic and chi-square test of heterogeneity. To examine the robustness of pooled results, we also conducted fixed-effects meta-analyses for trials, and compared the results between the fixed- and random-effects model.

Because of the substantial difference in quality of life measurements and insufficient reporting of data (e.g., lack of variation parameters), we were unable to pool these data in the studies of screening versus no screening.

For the rescreening studies, we also qualitatively summarized 30-day mortality, number of AAA operations, and quality of life due to limited data and differences in patient population and length of followup.

### Data Synthesis for KQs 4 and 5 (Benefits and Harms of Treatment of Small AAA)

We conducted meta-analyses of trials of open surgery versus surveillance and EVAR versus surveillance in the management of small AAA (3.0 to 5.5 cm).

#### Main Analyses

We conducted DerSimonian and Laird random-effects meta-analyses of trials reporting all-cause mortality, AAA-related mortality, AAA rupture, 30-day operative mortality, and surgical procedure use using the estimate of heterogeneity from the Mantel-Haenszel model. We had planned to use HRs as the measure of effect for pooling of trials for time to all-cause mortality, AAA-related mortality, and rupture, since the length of patient followup varied significantly within studies (e.g., 3 to 6 years in the U.K. Small Aneurysm Trial [UKSAT]) and because HR is the most appropriate measure of effect for time-to-event data. However, the time-to-event data were only available for pooling all-cause mortality. We thus reported pooled risk ratios for all outcomes, in addition to the pooled HR for all-cause mortality. For trials with zero events, we used a continuity correction of 0.5. All statistical testing was two-sided and 0.05 was considered significant. We examined heterogeneity across trials with the I^2^ statistic and chi-square test of heterogeneity.

#### Exploration of Heterogeneity

Among all the prespecified hypotheses, data were available for exploring heterogeneity of effect only for all-cause mortality by AAA diameter at baseline and sex in two trials comparing open surgery versus surveillance. To undertake our subgroup analyses, we initially pooled the results of each subgroup across studies (e.g. data for males from both the UKSAT and the Aneurysm Detection and Management [ADAM] trial) and subsequently tested for the interaction across the subgroups.

#### Sensitivity Analyses

We undertook the following sensitivity analyses to check the robustness of results:

- For all-cause mortality, we conducted random-effects meta-analyses of trials reporting risk ratios, and we qualitatively compared the pooled estimates using HRs versus risk ratios.
- For those outcomes with a very low event rate (e.g., AAA-related mortality), we conducted fixed-effects meta-analyses, and we qualitatively compared the results between a fixed- and random-effects model.
- For trials with zero events, we used an alternative continuity correction (i.e., 0.005).

Because of the very small number of trials included in each of the meta-analyses, we did not apply funnel plots to examine the publication bias.

#### Additional Analyses

The data reported on adverse effects of open surgery and EVAR, such as quality of life and surgical complications, did not allow for quantitative analyses. We thus summarized these data qualitatively by the type of intervention (open surgery vs. EVAR) and adverse outcome.

## USPSTF Involvement

This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. The authors worked with three USPSTF liaisons at key points throughout the review process to develop and refine the scope, analytic framework, and KQs; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment, or synthesis. AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts, including representatives of professional societies and federal agencies. The final published systematic evidence review was revised based on comments from these external reviewers.