# Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) commissioned this report to update the previous recommendation on abdominal aortic aneurysm (AAA) screening. In 2005, the USPSTF found good-quality evidence to recommend one-time screening for AAA by ultrasonography in men ages 65 to 75 years who have ever smoked (B recommendation).1 The USPSTF concluded that the benefits of screening do not clearly outweigh the possible harms in men ages 65 to 75 years who have never smoked, and thus made no recommendation for or against screening for AAA in this population (C recommendation).1 Also, based on the low prevalence of the condition and its sequealae and the presence of competing risks, the USPSTF recommended against routine screening for AAA in women age 65 years and older (D recommendation).1

This study applied systematic review methods to systematically assess the evidence regarding the benefits and harms of AAA screening and alternative strategies for managing screen-detected small AAA.

## Background

### Condition Definition

An AAA is a weakening in the wall of the abdominal section of the aorta, which is the largest artery in the body.2 Once a section of the aortic wall is weakened, the pressure from the blood flowing through causes the aorta to bulge or balloon, resulting in the formation of an aneurysm.3 A large proportion of AAAs are asymptomatic until the development of rupture. AAA rupture can be acute and is life-threatening.

The most accepted definition of an AAA is based on the diameter of the artery, with a diameter of 3.0 cm or larger considered to be an aneurysm.4 This is more than two standard deviations (SDs) above the average diameter of the abdominal aorta (2.0 cm) in both men and women.5 The abdominal aorta diameter varies somewhat by age, sex, and body size, which may influence the accuracy of this definition in some subgroups.6 An AAA is also defined as a maximum infrarenal aortic diameter of at least 1.5 times larger than the expected infrarenal aortic diameter.4 This definition, however, is less frequently used.

### Prevalence and Burden of Disease

A number of population-based screening studies conducted in the United States, United Kingdom, Australia, Sweden, and Italy have shown that AAA affects 1.6 to 7.2 percent of the general population age 50 years and older.7-16 Of note, in the past year, there have been several studies from established population-based screening programs in men age 65 years and older reporting declines in AAA prevalence in men over the past two decades in the United Kingdom,17,18 New Zealand,19 and Sweden,11 with reported prevalence ranging from 1.5 to 1.7 percent. The prevalence differs substantially by sex (1.6% to 8.8% in men vs. 0.2% to 6.2% in women), and the ratio of prevalence is generally 4 to 15 times greater in men than women.7,10,20 One recent study in 70-year-old women in Sweden reports a similar decline in the prevalence of AAA in women (approximately 0.4%).11 The prevalence of AAA appears to increase with age. In the Western Australian study, for example, the prevalence is 4.8 percent in the population ages 65 to 69 years, 7.6 percent in ages 70 to 74 years, 9.7 percent in ages 75 to 78 years, and 10.8 percent in ages 80 to 83 years.8 Ninety percent or more of identified aneurysms, however, are below the threshold for immediate surgery (3.0 to 5.5 cm).8,9,11,21,22

Each year, approximately 200,000 people are diagnosed with AAA in the United States, about 15,000 of whom develop AAAs large enough to be considered high risk for rupture.3,23 A rupture is often fatal, and an estimated 59 to 83 percent of patients die prior to hospitalization.24 The operative mortality (in-hospital or 30-day) of patients who survive until surgery has been estimated to be 41 percent. Thus, at most, 10 to 25 percent of individuals with ruptured AAAs survive to hospital discharge. Almost all deaths from ruptured AAAs occur after age 65 years.25

Data on the total societal economic burden of AAA are currently not available. Hospital discharge data show that patients with unruptured AAAs are hospitalized for an average of 6.7 days, presumably reflecting surgical treatment, with cumulative costs exceeding $59,000. In patients discharged after a ruptured AAA, the average hospital stay is 10.7 days and the average cost is more than $93,000.^26^ The economic burden of AAA would be substantially larger if indirect costs (e.g., disability) were taken into account.

### Etiology and Natural History

Although the direct causes for the development of AAA have not been fully understood, studies have suggested that smoking,27,28 atherosclerosis,29,30 and inflammation31,32 may all contribute to the development of AAA. Genetic predisposition may also lead to AAA development, and polymorphisms in several genes associated with AAA development have been identified.33,34

While the expansion rate of AAAs can vary significantly, the reported average growth rate of aneurysms measuring between 3.0 and 5.5 cm is 0.2 to 0.3 cm annually.4 The rate of expansion accelerates for larger aneurysms, ranging from a slow increase of 1.1 mm per year in ectatic aortas (2.5 to 2.9 cm in diameter)35 to 4.9 mm per year for larger aneurysms (4.0 to 4.9 cm).36 While a rapid rate of aneurysm expansion of more than 1 cm per year is commonly used in decisionmaking about elective repair of AAAs measuring smaller than 5.5 cm, the predictive value of expansion as an index of rupture risk is less clear.37

The annual risk of aneurysm rupture varies substantially. There is zero annual rupture risk for AAAs measuring between 3.0 and 3.9 cm, while aneurysms measuring 4.0 to 4.9 cm have a 1 percent annual rupture risk and those measuring 5.0 to 5.99 cm have an 11 percent annual rupture risk.38-40 Although women have a much lower prevalence of AAA, they are two to four times more likely to have aneurysm rupture than men (based on the findings of a single study).41

### Risk Factors

#### Risks Factors for Developing AAA

Significant risk factors for the development of AAA include advanced age,42 male sex,20 smoking,4,43,44 and family history of AAA.4,45,46 Other potential risk factors include a history of other vascular aneurysms,47 taller height,48 coronary artery disease,48 cerebrovascular disease,47 atherosclerosis,48 hypercholesterolemia,48 and hypertension.4,48 In recent years, genomewide association studies have shown an association between AAA development and mutations on certain chromosomes, specifically chromosome 9p21.^4,49^ Protective factors include African American race, female sex, and diabetes mellitus.50

#### Risk Factors for AAA Growth

A rigorous systematic review and individual patient data meta-analysis of 18 studies involving 15,475 patients examined the factors affecting the growth of small AAA.51 Among all factors examined—including age, sex, smoking, body mass index, diabetes, arterial blood pressure, pulse pressure, and history of cardiovascular disease (CVD)—smoking was the only risk factor that was independently associated with the increased risk of small AAA growth (point growth rate, 0.35 [95% CI, 0.23 to 0.48 mm per year]), and diabetes was independently associated with lower risk of AAA growth (-0.51 [95% CI, -0.70 to -0.32 mm per year]). Age, sex, arterial blood pressure, pulse pressure, and history of CVD were statistically associated with AAA growth in unadjusted analyses; the apparent associations became nonstatistically significant in adjusted analyses.

#### Risk Factors for AAA Rupture

If the aneurysm is allowed to expand without intervention, or if the initial size of the aneurysm is large, the risk of aneurysm rupture is significant.38,39,52-55 Older age, female sex, smoking, and higher arterial or pulse blood pressure are also associated with increased risk of rupture in patients with small AAA.51 The rupture risk in women has been reported to be almost four times greater than the rupture risk in men (hazard ratio [HR], 3.76 [95% CI, 2.58 to 5.47]).51 In addition, current smokers have been reported to have double the risk of aneurysm rupture than ever smokers or nonsmokers (HR, 2.02 [95% CI, 1.33 to 3.06]). Other potential pathogenic factors contributing to rupture include peak AAA wall stress56,57 and a rapidly progressing expansion rate.4,24,52,58

### Rationale for and Types of Screening/Screening Strategies

Identifying screening strategies that could reduce mortality and other adverse health outcomes is critical, since most AAAs are asymptomatic and have a high mortality rate if allowed to progress to rupture. Several strategies, including ultrasound, computed tomography (CT), and physical examination, may be used to identify AAA.

Ultrasonography is noninvasive, is easy to perform, and has high sensitivity (94% to 100%) and specificity (98% to 100%)4,24,59-62 for detecting AAA. In addition, it has demonstrated high rates of reproducibility and is low in cost. In 1 to 3 percent of patients, however, it may be impossible to see the aorta due to bowel gas or obesity.63,64 There are four aspects of aortic measurement: plane of acquisition, axis of measurement, position of calipers, and selected diameter. Trials vary in terms of reporting the specific technique, especially whether inner to inner wall versus outer to outer wall measurements are used.65 Nevertheless, ultrasound screening has been widely accepted as the primary approach for detecting AAA by both primary care physicians and vascular surgeons.4,24,44 The guidelines of both the Society for Vascular Surgery and the European Society for Vascular Surgery recommend ultrasound as the primary screening tool. Ultrasound has also been the primary modality studied in large population-based screening studies of AAA.13,14,66,67

CT scanning is another method that can be used to detect AAA. CT scans are more reproducible than ultrasound, but the size of the aneurysms detected by CT are generally 2 mm larger than that measured by ultrasound.24,68 CT scans have also shown relatively high sensitivity (90%) and specificity (91%) for the detection of symptomatic AAA.69 The Society for Vascular Surgery has recommended the use of CT scanning for operative planning due to its ability to determine the morphology of the AAA and the presence of renal arteries and occlusive disease.24

While physical examination for the detection of AAA has also been used in practice, such examinations have a low sensitivity. A good-quality case-control study estimated the sensitivity of detecting an AAA of 3.0 cm or larger to be 68 percent (95% CI, 60% to 76%), with a specificity of 75 percent (95% CI, 68% to 82%).70 A meta-analysis of 15 cohort screening studies of asymptomatic patients estimated sensitivity to be even lower, at 39 percent.71 This approach is not recommended for screening or preoperative planning.

### Interventions/Treatment

The initial management options for a screen-detected AAA are defined by size. Patients with small AAAs (diameter of <5.5 cm) may receive regular surveillance or pharmacotherapy from their primary care physician, or are occasionally referred to vascular surgeons for elective surgery for rapid growth (e.g., 1 cm per year).24 When the AAA diameter reaches 5.5 cm or larger, elective open surgery or endovascular repair (EVAR) is recommended.4,24 Emergency surgery is needed for ruptured AAAs irrespective of diameter, although the risk of rupture of small AAA is very low.38-40

#### Interventions for Small AAA

A number of interventions exist for managing small AAA (i.e., 3.0 to 5.4 cm), including surveillance, pharmacotherapy, and, rarely, surgery (open or EVAR). Surveillance aims to monitor the expansion rate of the aneurysm and initiate surgery when the aneurysm reaches 5.5 cm.4,24 Pharmacotherapy, a new treatment option for small AAA, is often used to slow aneurysm expansion. Currently used pharmaceutical agents include statins, angiotensin-converting enzyme (ACE) inhibitors, and antibiotics. Surgery, particularly EVAR, is an alternative treatment for small AAA.72 The risk-benefit profile of EVAR, however, needs to be fully considered.

#### Interventions for Large AAA

Management strategies for large AAA (≥5.5 cm) include open surgery and EVAR to avoid rupture.4,24,44 Open surgical repair, the conventional method for repairing large AAA, has been substantially tested in randomized trials.24 Both the American and European Vascular Societies recommend open repair for aneurysms measuring larger than 5.5 cm.4,24,44 In an open repair, a vascular surgeon opens a patient's abdomen and replaces the weakened section of the aorta with an aortic graft.3,24 The graft is a sturdy plastic tube that allows blood to easily pass through the artery and eliminates much of the risk of future AAA rupture.3,24 Open repair requires hospitalization for 4 to 7 days, and recovery typically takes 6 weeks to 3 months.

EVAR is an alternative option to repair large AAA.73 First introduced in 1991,^74^ this technique has largely replaced open surgical repair over the last decade, especially for uncomplicated aneurysm repairs. In the United States, the annual number of EVAR procedures has increased six-fold since 2000.^24^ Less invasive than open repair,3,24,73 EVAR is performed by threading catheters through the blood vessels to replace the weakened section of the aorta with an endovascular stent graft. The length of hospitalization is usually 2 to 3 days, and the overall recovery is typically shorter than recovery from open repair.3

EVAR has advantages over open surgery, such as reduction in operative time, avoidance of general anesthesia, less trauma and postoperative pain, and reduced blood loss, from both intact and ruptured AAAs.4,24,73 However, it has a higher reintervention rate than open repair because the graft is more likely to not seal properly, causing blood to begin to refill the aneurysm.3,4 Typically, patients require followup visits with either ultrasound or CT imaging scans at 1, 6, and 12 months after EVAR, followed by annual visits for the rest of their lives.3,73,75 If the patient experiences frequent problems after EVAR, conversion to open repair may be necessary.4

Three major trials (EVAR trial 1,76-78 Open Versus Endovascular Repair trial,79 and Dutch Randomized Endovascular Aneurysm Management trial78,80,81) comparing open and endovascular repairs for large AAA have suggested that EVAR has lower operative mortality than open surgery. There is no significant difference, however, in all-cause and aneurysm-related mortality between the two surgeries at a median followup of 6 years, and EVAR has higher risk of complications and reinterventions than open surgery. Another major trial (EVAR trial 2) comparing EVAR versus surveillance for large AAA unfit for open surgery also suggested that EVAR did not reduce all-cause and aneurysm-related mortality after a followup of 5 to 10 years.82,83

## Current Clinical Practice

Ultrasound is the primary technology used to screen patients for AAA.4,24 It is preferred to both physical examination and CT scans because it is inexpensive and noninvasive, can be easily implemented by both primary care and specialty clinics, and has optimal sensitivity and specificity.4

Once an AAA is detected, the management of the aneurysm depends on its size, the risk of rupture, and the risk of operative mortality.4 The current standard of care is to maintain ultrasound surveillance at regular intervals for patients with small AAAs (3.0 to 5.4 cm) because the risk of rupture is negligible.4 The Society for Vascular Surgery recommends followup surveillance with ultrasound every 3 years for healthy patients with AAAs measuring between 3.0 and 3.4 cm in diameter, at 12-month intervals for AAAs measuring 3.5 to 4.4 cm in diameter, and at 6-month intervals for AAAs measuring between 4.5 and 5.4 cm in diameter.24 According to the Society for Vascular Surgery, however, the quality of evidence supporting this recommendation is low.24

The universal standard for elective repair is that patients with AAAs with a diameter of 5.5 cm or larger should be referred to a vascular surgeon for surgical intervention with either open repair or EVAR.4,24,44,73 This recommendation is based on randomized, controlled trials (RCTs) with populations consisting mainly of men; as a result, the aneurysm size needed for surgical intervention may be different in women.4,73

## Previous USPSTF Recommendation

In 2005, the USPSTF found good evidence to recommend one-time screening for AAA by ultrasonography in men ages 65 to 75 years who have ever smoked (B recommendation). The USPSTF concluded that the benefits of screening did not clearly outweigh the harms in men ages 65 to 75 years who have never smoked and did not make a recommendation for or against screening for AAA in this population (C recommendation). The USPSTF recommended against routine screening for AAA in women (D recommendation).1

## Previous USPSTF Conclusions

The USPSTF found good-quality evidence that screening for AAA and surgical repair of large AAA (≥5.5 cm) in men ages 65 to 75 years who have ever smoked leads to decreased AAA-specific mortality. There was good evidence that ultrasound is an accurate screening test for AAA when performed in a setting with adequate quality assurance. There was also good-quality evidence of important harms of screening and early treatment, including an increased number of surgeries, with clinically significant morbidity and mortality, as well as short-term psychological harms. Based on the moderate magnitude of net benefit, the USPSTF concluded that the benefits of screening for AAA in men ages 65 to 75 years who have ever smoked outweighed the harms.1

The USPSTF also found good-quality evidence that screening for AAA in men ages 65 to 75 years who have never smoked leads to decreased AAA-specific mortality. There is, however, a lower prevalence of large AAA in men who have never smoked compared with men who have ever smoked; therefore, the potential benefit from screening in men who have never smoked is small. There was good-quality evidence that screening and early treatment led to important harms, including an increased number of surgeries, with associated clinically significant morbidity and mortality, and short-term psychological harms.

Based on the available evidence at the time of the recommendation statement, the prevalence of large AAA in women was determined to be low, leaving only a small number of AAA-related deaths that could be prevented by screening. There was good-quality evidence that screening and early treatment resulted in important harms, including an increased number of surgeries, with associated morbidity and mortality, and psychological harms. The USPSTF concluded that the harms of screening women for AAA outweighed the benefits.1