# Additional Meta-Analysis Figures

Appendix K Figure 1 Sensitivity Analysis of AAA-Related Mortality in One-Time Screening Trials (KQ 1)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 2 Pooled Analysis of AAA-Related Mortality in One-Time Screening Trials (Peto Odds Ratio)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 3 Pooled Analysis of AAA-Related Mortality in One-Time Screening Trials (Outcome Data Pooled at the Longest Followup)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 4 Funnel Plot of AAA-Related Mortality at 3 to 5 Years in One-Time Screening Trials (KQ 1)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 5 Sensitivity Analyses of All-Cause Mortality in One-Time Screening Trials (KQ 1)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 6 Pooled Analysis of All-Cause Mortality in One-Time Screening Trials (Outcome Data Pooled at Longest Followup)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 7 Funnel Plot of All-Cause Mortality at 3 to 5 Years in One-Time Screening Trials (KQ 1)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 8 Sensitivity Analyses of AAA Rupture in One-Time Screening Trials (KQ 1): Hazard Ratios

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 9 Pooled Analysis of AAA Rupture in One-Time Screening Trials (Outcome Data Pooled at the Longest Followup)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 10 Funnel Plot of AAA Rupture at 3 to 5 Years in One-Time Screening Trials (KQ 1)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 11 Pooled Analysis of All-Cause Mortality, AAA-Related Mortality, and Rupture in Open Surgery vs. Surveillance Trials at 5-Year Followup (Fixed-Effects Model) (KQ 4)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 12 Pooled Analysis of Surgical Procedures to Repair AAA in Trials of Early Open Surgery or EVAR vs. Surveillance (KQ 5)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 13 Pooled Analysis of All-Cause Mortality, AAA-Related Mortality, and Rupture in EVAR vs. Surveillance Trials (Fixed-Effects Model) (KQ 4)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 14 Pooled Analysis of Surgical Procedures in Patients Receiving Pharmacotherapy vs. Placebo (KQ 5)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.

Appendix K Figure 15 Pooled Analysis of All-Cause Mortality in Trials of Antibiotics vs. Placebo (Fixed-Effects Model) (KQ 4)

Appendix K contains additional meta-analysis figures related to all key questions, including senstivity analyses, data pooled at the longest followup, and funnel plots. The results displayed in these figures are referenced in the Results section, but not discussed at length. They are included here for informational purposes only.