# AAA Clinical Recommendations From Expert Groups

Expert Group | Target Group | Starting Age | Stopping Age | Frequency of Screening | Surveillance | Intervention(s) | Recommendation Grade
USPSTF, 2005^1^ | Men who have ever smoked | 65 | 75 | One time | NR | EVAR or OSR if AAA ≥5.5 cm | B Recommendation The service is recommended.
ACC, 2005^168^ | Men who are siblings or offspring of patients with AAA | ≥60 | 75 | One time | Every 6–12 months if AAA 4.0–5.4 cm; every 2–3 y if AAA smaller than 4.0 cm | Elective open repair if AAA ≥5.5 cm and low- or average-risk patient; endograft repair if AAA ≥5.5 cm and high-risk patient | Class I Recommendation that procedure or treatment is useful/effective. Level of Evidence: B Evidence from single RCT or nonrandomized studies.
ACC, 2005^168^ | Men ages 65–75 y who ever smoked | 65 | 75 | One time | Every 6–12 months if AAA 4.0–5.4 cm; every 2–3 y if AAA smaller than 4.0 cm. | Elective open repair if AAA ≥5.5 cm and low- or average-risk patient; endograft repair if AAA ≥5.5 cm and high-risk patient. | Class IIA Recommendation in favor of treatment or procedure being useful/effective. Level of Evidence: B Some conflicting evidence from single RCT or nonrandomized studies.
CSVS, 2007^167^ | Men | 65 | 75 | Every 3–5 y | Policy is unclear for AAA 4.4–5.4 cm; annually if AAA 3.0–4.4 cm | Surgical repair (not specified) if AAA ≥5.5 cm | Grade 1A Evidence obtained from at least 1 properly randomized controlled trial or 1 large epidemiological study. Evidence sufficient for universal use.
CSVS, 2007^167^ | Women age 65 y or older with multiple risk factors (smoking history, CVD, family history of AAA) | 65 | NR | Every 3–5 y | Policy is unclear for AAA 4.4–5.4 cm; annual rescreening if AAA 3.0–4.4 cm | Surgical repair (not specified) if AAA ≥5.5 cm | Grade 3C Opinions of respective authorities, based on clinical experience, descriptive studies, or reports of expert committees. Evidence not based on RCTs.
CSVS, 2007^167^ | Women age 65 y or older, all adults age <65 y, and men age 75–80 y | NA | NA | NA | NA | NA | Grade 3C Opinions of respective authorities, based on clinical experience, descriptive studies, or reports of expert committees. Evidence not based on RCTs.
CCS, 2005^169^ | Men ages 65–74 y | NR | NR | Every 3–5 y | Repeat ultrasound every 6 months if AAA ≥4.5 cm, repeat in 1 y if AAA 4.0–4.5 cm; repeat in 2 y if AAA 3.5–3.9 cm; repeat in 3 y if AAA 3.1–3.4 cm | Referral to vascular surgeon if AAA ≥4.5 cm; surgical repair (not specified) if AAA >5.5 cm in men and >4.5 in women. Consider surgical repair if growth >1 cm in 1 y | Grade 1A Evidence obtained from at least 1 properly randomized controlled trial or 1 large epidemiological study. Evidence sufficient for universal use.
CCS, 2005^169^ | Women age 65 y or older with CVD and positive family history of AAA | 65 | NR | Every 3–5 y | Repeat ultrasound every 6 months if AAA ≥4.5 cm, repeat in 1 y if AAA 4.0–4.5 cm; repeat in 2 y if AAA 3.5–3.9 cm; repeat in 3 y if AAA 3.1–3.4 cm | Referral to vascular surgeon if AAA ≥4.5 cm; surgical repair (not specified) if AAA >5.5 cm in men and >4.5 cm in women. Consider surgical repair if growth >1 cm in 1 y | Grade 3C Opinions of respective authorities, based on clinical experience, descriptive studies, or reports of expert committees. Evidence not based on RCTs.
SVS, 2009^24^ | Men age 50 y or older and family history of AAA | 50 | 64 | One time | Every 6 months if AAA 4.5–5.4 cm; at 1 y if AAA 3.5–4.4 cm; repeat in 3 y if AAA 3.0–3.4 cm; repeat in 5 y if AAA 2.6–2.9 cm | Surgical repair if fusiform AAA ≥5.5 cm, secular AAA, young healthy patients and especially women with AAA 5.0–5.4 cm, statins, smoking cessation, ACE inhibitors/angiotensin receptor blockers; EVAR is associated with lower risk than OSR | Grade 3C Opinions of respective authorities, based on clinical experience, descriptive studies, or reports of expert committees. Evidence not based on RCTs.
SVS, 2009^24^ | Men age 65 y or older; as early as 55 yearsfor those with a family history of AAA | 65 (55 if family history of AAA) | NR | One time | Repeat every 6 months if AAA 4.0–4.5 cm; annual examination if AAA 3.0–4.0 cm | Refer to a vascular specialist if AAA >4.5 cm; surgical repair if >5.5 cm; EVAR is associated with lower risk than OSR | Level of recommendation: Strong Benefits > Risks Quality of evidence: High Additional research is considered very unlikely to change confidence in the estimate of effect.
SVS, 2009^24^ | Women age 65 y or older with a family history of AAA or who have smoked | 65 | NR | One time | Repeat every 6 months if AAA 4.0–4.5 cm; annual examination if AAA 3.0–4.0 cm | Refer to a vascular specialist if AAA >4.5 cm; surgical repair if >5.5 cm; EVAR is associated with lower risk than OSR | Level of recommendation: Strong Benefits > Risks Quality of evidence: Moderate Further research is likely to have an important impact on in the estimate of effect.

Abbreviations: AAA = abdominal aortic aneurysm; ACC = American College of Cardiology; ACE = angiotensin-converting enzyme; CCS = Canadian Cardiovascular Society; CSVS = Canadian Society for Vascular Surgery; CVD = cardiovascular disease; EVAR = endovascular aneurysm repair; NR = not reported; OSR = open surgical repair; RCT = randomized, controlled trial; SVS = Society of Vascular Surgery; USPSTF = U.S. Preventive Services Task Force.