# Quality of Life Results for Treatment Studies (KQs 4 and 5)

Appendix I Table 1 Quality of Life Results in Studies of Treatment for Small AAA (KQs 4 and 5)

Study | QOL screening method | Time period | Treatment Group | N Analyzed | QOL scores, mean (SD)^¶^ | Mean difference (95% CI), p-value
Open surgery vs. surveillance
UKSAT132 | MOS subscale^*^ | Baseline | IG | 480 | Physical function: 64.2 (30.7) Mental health: 80.2 (17.2) | Physical function: -2.3 (-6.0 to 1.5); NR Mental health: 0.7 (-1.5 to 2.8); NR
UKSAT132 | MOS subscale^*^ | Baseline | CG | 512 | Physical function: 66.5 (29.3) Mental health: 79.5 (17.0) | Physical function: -2.3 (-6.0 to 1.5); NR Mental health: 0.7 (-1.5 to 2.8); NR
UKSAT132 | MOS subscale^*^ | 12 months post-randomization | IG | 429 | Physical function: 62.1 (29.9) Mental health: 81.7 (17.9) Mean difference from BL: Physical function: -3.5 (-6.1 to -0.8) Mental health: 0 (-1.5 to 1.5) | Physical function: 1.7 (-2.3 to 5.7) Mental health: 2.1 (-0.4 to 4.5)
UKSAT132 | MOS subscale^*^ | 12 months post-randomization | CG | 436 | Physical function: 60.3 (30.2) Mental health: 79.6 (18.6) Mean difference from BL: Physical function: -6.2 (-8.8 to -3.7) Mental health: 0 (1.7 to 1.8) | Physical function: 1.7 (-2.3 to 5.7) Mental health: 2.1 (-0.4 to 4.5)
EVAR vs. surveillance
CAESAR114 | SF-36^*^ | Baseline through 6 months post-randomization | IG | 173 | Mean difference (95% CI) from BL: Overall QOL: 4.6 (2.3 to 7) Physical functioning: -0.6 (-3.7 to 2.4) Mental health: 5.2 (2.8 to 7.5) | IG vs. CG Overall QOL: 5.4 (2.1 to 8.8); p=0.002 Physical function: 3.8 (0.5 to 7.2); p=0.02 Mental health: 6.0 (2.7 to 9.3); p=0.0005
CAESAR114 | SF-36^*^ | Baseline through 6 months post-randomization | CG | 166 | Mean difference (95% CI) from BL: Overall QOL: -0.8 (-3.2 to 1.6) Physical functioning: -4.3 (-7.3 to -1.2) Mental health: -0.8 (-3.2 to 1.5) | IG vs. CG Overall QOL: 5.4 (2.1 to 8.8); p=0.002 Physical function: 3.8 (0.5 to 7.2); p=0.02 Mental health: 6.0 (2.7 to 9.3); p=0.0005
CAESAR114 | SF-36^*^ | Baseline through end of followup^§^ | IG | 173 | Mean difference (95% CI) from BL: Overall QOL: 4.6 (2.3 to 7) Physical functioning: -0.6 (-3.7 to 2.4) Mental health: 5.2 (2.8 to 7.5) | IG vs. CG Overall QOL: 2.4 (-1.7 to 6.6); p=0.25 Physical function: 1.5 (-2.6 to 5.5); p=0.48 Mental health: 2.0 (-2.4 to 6.4); p=0.38
CAESAR114 | SF-36^*^ | Baseline through end of followup^§^ | CG | 166 | Mean difference (95% CI) from BL: Overall QOL: -6.3 (-9.3 to -3.4)║ Physical functioning: -8.2 (-12.0 to -4.4) Mental health: 4.8 (-7.9 to -1.7)║ | IG vs. CG Overall QOL: 2.4 (-1.7 to 6.6); p=0.25 Physical function: 1.5 (-2.6 to 5.5); p=0.48 Mental health: 2.0 (-2.4 to 6.4); p=0.38
Pharmacotherapy vs. surveillance
Lindholt 1999^117^ | ScreenQL^*,†^ | Baseline through 2 y | IG | 30 | NR | Overall QOL: -5.83 (6.2)^‡^; p=0.05 Emotional domain: -0.35 (2.1)^‡^; p=0.59 Health perception: -1.39 (2.98)^‡^; p=0.13
Lindholt 1999^117^ | ScreenQL^*,†^ | Baseline through 2 y | CG | 24 | NR | Overall QOL: -1.70 (5.5)^‡^; p=0.07 Emotional domain: 0.00 (2.0)^‡^; p=0.69 Health perception: -0.38 (2.10)^‡^; p=0.30
PAT 2002^116^ | SF-36^*^ | Baseline | IG | 276 | Physical function: 70.8 (23.9) Mental health: 78.9 (17.3) | Physical function: p=0.11 Mental health: p=0.45
PAT 2002^116^ | SF-36^*^ | Baseline | CG | 272 | Physical function: 74.1 (24.0) Mental health: 77.8 (17.9) | Physical function: p=0.11 Mental health: p=0.45
PAT 2002^116^ | SF-36^*^ | 1 month post-randomization | IG | 276 | Physical function: 68.9 (18.9) Mental health: 78.9 (17.6) | Physical function: p=0.006 Mental health: p=0.58
PAT 2002^116^ | SF-36^*^ | 1 month post-randomization | CG | 272 | Physical function: 74.4 (23.8) Mental health: 78.3 (17.5) | Physical function: p=0.006 Mental health: p=0.58

* Lower score denotes poorer status.

† A validated generic and global QOL questionnaire with 24 items evaluating 6 categories: general QOL, emotional health, physical health, psychosomatic distress, social and family functions, and marriage.

‡ Mean (SD); change from BL in each group, not IG vs. CG.

§ Mean, 3 y from BL (SD, 1.2 y).

║ p<0.01.

¶ Only summary scores reported here. For complete subscales please see full text.

Abbreviations: BL = baseline; CAESAR = Comparison of Surveillance Versus Aortic Endografting for Small Aneurysm Repair; CG = control group; EVAR = endovascular aneurysm repair; IG = intervention group; MOS = Medical Outcomes Study; NR = not reported; PAT = Propanolol Aneurysm Trial; QOL = quality of life; SF-36 = Short-Form 36-Item Health Survey; UKSAT = UK Small Aneurysm Trial.