# Methodological and Patient Characteristics of Treatment Studies (KQs 4 and 5)

Appendix H Table 1 Methodological and Intervention Characteristics of Included Treatment Studies (KQs 4 and 5)

Study, Year | Study quality | N randomized | Country | Mean followup, y | Intervention | Control | Benefit outcomes reported | Harm outcomes reported
Open surgery vs. surveillance
UKSAT, 1998^41,108, 109,111,132^ | Good | 1,090 | United Kingdom | 4.6 | Elective open surgery within 3 months of AAA identification | Surveillance until AAA reached 5.5 cm, rapidly increased in diameter (>1 cm/y) or developed symptoms | 1, 2, 3 | 1, 2, 3
ADAM, 2002^106^ | Good | 1,136 | United States | 4.9 | Elective open surgery within 6 weeks of AAA identification | Surveillance until AAA reached 5.5 cm, enlarged by at least 0.7 cm in 6 months/1.0 cm in 1 y, or symptoms developed | 1, 2, 3 | 1, 2, 4
EVAR vs. surveillance
CAESAR, 2010^113, 114^ | Fair | 360 | Italy | 2.6^‡^ | Patients received surgery via EVAR as soon as possible | Surveillance until AAA reached 5.5 cm in diameter, a rapid increase of >1 cm/y was found, or the aneurysm became symptomatic | 1, 2, 3 | 2
PIVOTAL, 2010^115^ | Fair | 728 | United States | 1.7 | Patients underwent EVAR ≤30 days of randomization | Surveillance until AAA reached 5.5 cm or enlarged ≥0.5 cm between any two 6-month assessments | 1, 2, 3 | 1, 2
Pharmacotherapy vs. placebo
Mosorin, 2001^118^ | Fair | 32 | Finland | 1.8 | 150 mg doxycycline daily | Placebo | 1, 4
Karlsson, 2009^119^ | Fair | 247 | Sweden | 1.5 | 600 mg azithromycin once daily for 3 days, followed by 600 mg once a week | Placebo | 1, 2^*^, 4 | 2
Vammen, 2001^120^ | Good | 92 | Denmark | 2 | 300 mg oral roxithromycin once daily for 28 days | Placebo | 1, 4^†^ | 2
PAT, 2002^116^ | Good | 552 | Canada | 2.5 | 20 mg propranolol twice a day; increased to 40 mg after 1 week, 80 mg after 2 weeks, and 120 mg at 4 weeks. Target dose was 80–120 mg twice a day | Placebo | 1, 2, 3, 4 | 1, 2, 3
Lindholt, 1999^117^ | Fair | 54 | Denmark | 2 | 40 mg propranolol twice a day | Placebo | Not usable^§^ | 3
Registry studies
Golledge, 2007^122^ | Fair | NA | Australia | 3.2^‡^ | National audit examining the perioperative and intermediate results of EVAR for small AAA | NA | NA | 1, 2, 5
Peppelenbosch, 2003^123^ | Fair | NA | Europe | 1.7 | Audit of the EUROSTAR database of patients who had undergone elective EVAR for small AAA | NA | NA | 1, 2, 5

Benefit outcomes: 1=all-cause mortality; 2=AAA-related mortality; 3=rupture (fatal and nonfatal); 4=AAA growth rate.

Harm outcomes: 1=30-day operative mortality; 2=use of procedures (emergency and selective surgery); 3=quality of life; 4=major complications associated with AAA open repair; 5=major complications associated with EVAR.

* No AAA-related death was found in both groups.

† This study also reported 5-y followup data on growth rate.

‡ Median.

§ Due to a large loss to followup, efficacy data were not usable. However, these losses were due to adverse events so the harms data are included.

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = aAbdominal Aortic Aneurysm Detection and Management Study; CAESAR = Comparison of Surveillance vs. Aortic Endografting for Small Aneurysm Repair; N = sample size; NA = not applicable; EUROSTAR = European Collaborators on Stent-Graft Techniques for aAbdominal Aortic Aneurysm Repair; PAT = Propanolol Aneurysm Trial; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early; UKSAT = UK Small Aneurysm Trial.

Appendix H Table 2 Patient Characteristics of Included Treatment Studies (KQs 4 and 5)

Study | Major inclusion criteria | Mean age % Female | AAA diameter at baseline | % Current smoking | % Family history | % Diabetes | % CVD risk factors
Open surgery vs. surveillance
UKSAT108 | Patients ages 60–76 y with asymptomatic, small AAA (4.0–5.5 cm) | 69.3 17.5 | 4.6 | 37.1 | NR | 2.5 | Hypertension: 39 Probable ischemic heart disease: 14
ADAM106 | Patients ages 50–79 y with AAA 4.0–5.4 cm identified via CT within the previous 12 weeks | 68.1 0.8 | 4.7 | 39.2 | 12.9 | 9.8 | Coronary disease: 41.9 Cerebrovascular disease: 12.4 Hypertension: 56.4
EVAR vs. surveillance
CAESAR113 | Patients ages 50–80 y; nonsymptomatic AAA 4.1–5.4 cm in diameter measured by CT within the previous 3 months | 68.9 4.2 | 4.7 | 55.3 | NR | 13.6 | Coronary disease: 39.2 Hypertension: 75.3
PIVOTAL115 | Patients ages 40–90 y with AAA between 4.0 and 5.0 cm found by CT performed ≤3 months prior; eligible for EVAR | 70.5 13.4 | 4.4 | 91.0 | 23.5 | NR | MI: 31.3 CHF: 6.2 CAD: 55.4 PVD: 28.2 Hypertension: 77.8
Pharmacotherapy vs. surveillance
Mosorin, 2001^118^ | Aneurysm diameter perpendicular to the aortic axis of ≥3.0 cm in size or a ratio of infrarenal to suprarenal aortic diameter of ≥1.2 and a diameter <5.5 cm; followup of at least 6 months with 2 or more ultrasound examinations | 68.4 9.4 | 3.3 | 35.4 | NR | 15.1 | Hypertension: 40.2
Karlsson, 2009^119^ | Patents age ≤80 y with AAA 3.5–4.9 cm | 71^†^ 18.5 | NR | 40 | 14 | 4.5 | MI: 31.0 Stroke: 14.1 Hypertension: 62.5
Vammen, 2001^120^ | AAA ≥3.0 cm detected by ultrasound the day of study entry; exclusively men | 72.5 0 | 3.8 | 0.6^‡^ | NR | NR | NR
PAT, 2002^116^ | Asymptomatic small AAA (3.0–5.0 cm; some centers only, 3.0–4.5 cm) measured by ultrasound; no contraindications to study drug | 68.9 16 | 3.8 | 34.7 | NR | 6.2 | Angina: 14.8 Heart failure: 2.0 Claudication: 19.2 Hyperlipidemia: 33.6 Hypertension: 35.8 MI: 16.9 Stroke: 6.3
Lindholt, 1999^117^ | Men with AAA 3.0–4.9 cm | 69.2 0 | 3.4 | NR | NR | NR | NR
Registry Studies
Golledge, 2007^122^ | Patients had to have undergone EVAR treatment for small AAA (≤5.5 cm) | 75^†^ 16 | NR | 11 | NR | 11 | Hypertension: 67 Ischemic heart disease^*^: 54 CVD: 5 PVD: 26
Peppelenbosch, 2003^123^ | Patients in the EUROSTAR database who had undergone elective EVAR to repair an AAA; minimal followup of 1 month; vascular anatomy suitable for implantation of a stent graft | 69.7 7 | NR | NR | NR | NR | History of cardiac symptoms: 56

* Defined as angina, MI, arrhythmia, or heart failure.

† Median.

‡ Mean.

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal Aortic Aneurysm Detection and Management Study; CAD = coronary artery disease; CAESAR = Comparison of Surveillance Versus Aortic Endografting for Small Aneurysm Repair; CHF = congestive heart failure; CT = computed tomography; CVD = cardiovascular disease; EUROSTAR = European Collaborators on Stent-Graft Techniques for Abdominal Aortic Aneurysm Repair; EVAR = endovascular aneurysm repair; MI = myocardial infarction; NR = not reported; PAT = Propranolol Aneurysm Trial; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early; PVD = peripheral vascular disease; UKSAT = UK Small Aneurysm Trial.