# Methodological and Patient Characteristics of Rescreening Studies (KQ 2)

Appendix G Table 1 Methodological and Intervention Characteristics of Included Rescreening Studies (KQ 2)

Characteristic | D'Audiffret 2002^96^ | Deveraj 2008^98^ | Emerton 1994^102^ McCarthy 2003^126^ (5-y data) Crow 2001^103^ (12-y data) Darwood 2012^17^ (10-y data) | Hafez 2008^99^ | Lederle 2000^101^ | Lindholt 2000^100^ | Scott 2001^97^
Study Quality | Fair | Fair | Fair | Fair | Good | Fair | Fair
N | 223 | 999 | 50,130 | 22,961 | 15,098 | 6,339 | 1,011
N Analyzed | 223 | 358 | 189 (5 y) 625 (5 y) 129 (12 y) 547 (10 y) | 4,308 | 2,622 | 248 | 649
Country | US | UK | UK | UK | US | Denmark | UK
Mean length of followup, y | 5.9 | 4 | 12 | 5^*^ | 4 | 5 | 10
Intervention | Patients from the ADAM trial; rescreening annually after aortic diameters of 2.5–2.9 cm were identified | Patients from the Good Hope Hospital Screening Program; rescreening of abnormal aortas (2.6–2.9 cm) at intervals ranging from 3 months to annually | Patients from the Gloucestershire Aneurysm Screening Study; rescreening at 5 and 12 y after a normal AAA scan | Patients from the Chichester Trial; rescreening at different intervals based on size of aorta at initial screening (2.5–2.9 cm: every 2 y (or once after 5 y); 3–4.4 cm annually; 4.5–5.4 cm every 3 months). Those with AAA ≥5.5 cm were sent to a surgical consultation with a vascular surgeon | Patients from the ADAM trial; rescreening in those found to have no AAA 4 y after initial screening | Case/control study of the Viborg Trial; annual followup screenings for AAA >3.0 cm and <3.0 cm; those with aorta 25–29 mm were offered rescreening 3 to 5 y after initial screen; control group were those with no AAA | Individuals with normal-sized aortas at initial scan were rescreened every 2 y. Patients with AAA 3–4.5 cm were scanned annually; 4.5–5.9 cm every 3 months. Patients were referred to a vascular surgeon once their aneurysm reached ≥6 cm. (These patients were NOT Chichester trial participants.)
Benefit outcomes reported | 1, 2, 3 | 4 | 1, 2, 3, 4 | 2, 3, 4 | 1, 2 | 1^†^ | 2, 3, 4
Harm outcomes reported | 6 | NR | NR | 5,6 | NR | 6 | NR

Benefit outcomes: 1=all-cause mortality; 2=AAA-related mortality; 3=rupture (fatal and nonfatal); 4= AAA growth rate.

Harm outcomes: 5=30-day operative mortality; 6=use of procedures (emergency and selective surgery); 7=quality of life.

* Median.

† All-cause mortality reported, but not causes of death.

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal Aortic Aneurysm Detection and Management Study; NR = not reported.

Appendix G Table 2 Patient Characteristics of Included Rescreening Studies (KQ 2)

Study | Major inclusion criteria | Mean age % Female | % Current smoking | % Family history | % Diabetes | % CVD risk factors
D'Audiffret, 2002^96^ | Those with aortic diameters of 2.5–2.9 cm | 68.4 NR | 81.6 | 13.9 | 11.2 | PAD: 12.5 Hypertension: 49.8 Hypercholesterolemia: 17.5
Deveraj, 2008^98^ | Men found to have ectatic aortas (2.6–2.9 cm in diameter) at first scan with a minimum of 1-y followup | 74.8 0 | NR | NR | NR | NR
Emerton, 1994^102^ McCarthy 2003^126^ (5-y data) Crow 2001^103^ (12-y data) Darwood 2012^17^ (10-y data) | Men ages 65–66 y at the time of original study who had aortic diameters <2.6 cm | NR 0 | NR | NR | NR | NR
Hafez, 2008^99^ | Men age 65 y invited to screen for AAA and found to have small AAA | 65.6 0 | NR | NR | NR | NR
Lederle, 2000^101^ | VA patients ages 50–79 y without AAA (aortic diameters of ≤3.0 cm) who were part of the ADAM trial | 66.6 2.4 | No AAA: 14.6 AAA: 36.2 | No AAA: 6.0 AAA: 2.7 | No AAA: 17.6 AAA: 14.6 | Hypertension: 55.2 High cholesterol: 41.9 CAD: 43.3 Any atherosclerosis: 50.5
Lindholt, 2000^100^ | Men ages 65–73 y with either identified small AAA (2.5–2.9 cm) or those with a normal initial scan (along with 380 controls) | NR 0 | NR | NR | NR | NR
Scott, 2001^97^ | Male patients with a normal aorta on their initial scan at age 65 y | NR 0 | NR | NR | NR | NR

Abbreviations: AAA = abdominal aortic aneurysm; CAD = coronary artery disease; CVD = cardiovascular disease; NR = not reported; PAD = peripheral artery disease; VA = Department of Veterans Affairs.