# AAA Size and Prevalence in One-Time Screening Trials

Appendix F Table 1 Percent of Screened Population With AAA of the Specified Size

Trial | Total Scanned | Total AAA (prevalence) | ≥5.5 cm | 5.0 to 5.9 cm | 4.5 to 5.4 cm | 3.0 to 4.4 cm
MASS, 2002^13^ | 27,147 (men) | 1,333 (4.9) | 166 (0.6) | NR | 223 (0.8) | 944 (3.5)
Chichester, 1995^14^ | 5,394 (men and women) | 218 (4.0) | 19 (0.4) | 20 (0.4) | NR | 179 (3.3)^†^
Western Australian, 2004^16^ | 12,213 (men) | 875 (7.2) | 61 (0.5) | NR | 115 (0.9) | 699 (5.7)
Viborg, 2005^15^ | 4,860 (men) | 191 (3.9) | 24 (0.5) | NR | NR | NR

* AAA >6.0 cm.

† AAA of 3.0 to 4.0 cm.

Abbreviations: AAA = abdominal aortic aneurysm; NR = not reported.