# Methodological and Patient Characteristics of One-Time Screening Studies (KQs 1 and 3)

Appendix E Table 1 Methodological and Intervention Characteristics of Included One-time Screening Studies (KQs 1 and 3)

Appendix E Table 2 Patient Characteristics of Included One-time Screening Studies (KQs 1 and 3)