# Excluded Studies

Exclusion
E1. Study relevance
E2. Setting
E3. Population
E4. Study design; a. Not an included study design; b. Comparative effectiveness trial
E5. No relevant outcomes
E6. Interventions
E7. Study quality; a. High or differential attrition; b. Other issues
E8. Source document only
E9. Not relevant comparison
E10. Not relevant AAA diameter
E11. Not relevant screening tool

1 Multicentre aneurysm screening study (MASS): cost effectiveness analysis of screening for abdominal aortic aneurysms based on four year results from randomised controlled trial. BMJ. Nov. 16. 2002;325(7373):1135. KQ3E5. [pmid: 12433761].
2 Abdul-Hussien H, Hanemaaijer R, Verheijen JH, et al. Doxycycline therapy for abdominal aneurysm: Improved proteolytic balance through reduced neutrophil content. J Vasc Surg. 2009;49(3):741-9. KQ4E10. [pmid: 19268776].
3 Alcorn HG, Wolfson SK Jr., Sutton-Tyrrell K, et al. Risk factors for abdominal aortic aneurysms in older adults enrolled in The Cardiovascular Health Study. Arterioscler Thromb Vasc Biol. Aug. 1996;16(8):963-70. KQ1E5. [pmid: 8696960].
4 Ali ZA, Callaghan CJ, Ali AA, et al. Perioperative myocardial injury after elective open abdominal aortic aneurysm repair predicts outcome. Eur J Vasc Endovasc Surg. Apr. 2008;35(4):413-9. KQ5E9. [pmid: 18063394].
5 Alund M, Mani K, Wanhainen A. Selective screening for abdominal aortic aneurysm among patients referred to the vascular laboratory. Eur J Vasc Endovasc Surg. Jun. 2008;35(6):669-74. KQ1E5. [pmid: 18258461].
6 Armstrong PA, Back MR, Bandyk DF, et al. Optimizing compliance, efficiency, and safety during surveillance of small abdominal aortic aneurysms. J Vasc Surg. 2007;46(2):190-5. KQ5E4. [pmid: 17540533].
7 Arrington S, Ogata T, Davis PM Jr., et al. Aneurysm Outreach Inc., a nonprofit organization, offers community-based, ultrasonography screening for abdominal aortic aneurysms. Ann N Y Acad Sci. Nov. 2006;1085:291-3. KQ1E5. [pmid: 17182945].
8 Badger SA, O'Donnell ME, Sharif MA, et al. Advantages and pitfalls of abdominal aortic aneurysm screening in high-risk patients. Vascular. Jul. 2008;16(421):201-6. KQ1E4, KQ1E5, KQ2E4. [pmid: 18845100].
9 Badger SA, O'Donnell ME, Sharif MA, et al. Risk factors for abdominal aortic aneurysm and the influence of social deprivation. Angiology. Oct. 2008;59(5):559-66. KQ1E5. [pmid: 18818237].
10 Bailey MA, Dunne JA, Griffin KJ, et al. Systematic review and meta-analysis of the effects of statin therapy on abdominal aortic aneurysms. (Br J Surg 2011; 98: 362-353). Br J Surg. May. 2011;98(5):744-5. KQ4E4a. [pmid: 21462179].
11 Ballard DJ, Filardo G, Fowkes G, et al. Surgery for small asymptomatic abdominal aortic aneurysms. Cochrane Database Syst Rev. 2008;(4):CD001835. KQ4E8. [pmid: 18843626].
12 Bartoli MA, Thevenin B, Sarlon G, et al. Secondary procedures after infrarenal abdominal aortic aneurysms endovascular repair with second-generation endografts. Ann Vasc Surg. Feb. 2012;26(2):166-74. KQ5E10. [pmid: 22037143].
13 Basnyat PS, Aiono S, Warsi AA, et al. Natural history of the ectatic aorta. Cardiovasc Surg. Aug. 2003;11(4):273-6. KQ2E5. [pmid: 12802262].
14 Baxter BT, Pearce WH, Waltke EA, et al. Prolonged administration of doxycycline in patients with small asymptomatic abdominal aortic aneurysms: report of a prospective (Phase II) multicenter study. J Vasc Surg. Jul. 2002;36(1):1-12. KQ4E4a. [pmid: 12096249].
15 Bengtsson H, Bergqvist D, Ekberg O, et al. A population based screening of abdominal aortic aneurysms (AAA). Eur J Vasc Surg. Feb. 1991;5(1):53-7. KQ1E4a. [pmid: 2009986].
16 Bergqvist D. Pharmacological interventions to attenuate the expansion of abdominal aortic aneurysm (AAA) - a systematic review. Eur J Vasc Endovasc Surg. May. 2011;41(5):663-7. KQ4E8. [pmid: 21330159].
17 Bertero C, Carlsson P, Lundgren F. Screening for abdominal aortic aneurysm, a one-year follow up: an interview study. J Vasc Nurs. Sep. 2010;28(3):97-101. KQ3E5. [pmid: 20709266].
18 Biancari F, Mosorin M, Anttila V, et al. Ten-year outcome of patients with very small abdominal aortic aneurysm. Am J Surg. Jan. 2002;183(1):53-5. KQ4E4a. [pmid: 11869702].
19 Brady AR, Thompson SG, Greenhalgh RM, et al. Cardiovascular riskfactors and abdominal aortic aneurysm expansion: only smoking counts. Br J Surg. 2003;90:492-3. PMID: None. KQ2E10.
20 Brady AR, Thompson SG, Fowkes FG, et al. Abdominal aortic aneurysm expansion: risk factors and time intervals for surveillance. Circulation. Jul. 6. 2004;110(1):16-21. KQ4E4a. [pmid: 15210603].
21 Buckenham T, Roake J, Lewis D, et al. Abdominal aortic aneurysm surveillance: application of the UK Small Aneurysm Trial to a New Zealand tertiary hospital. N Z Med J. 2007;120(1251):U2472. KQ2E5, KQ5E4. [pmid: 17384700].
22 Collin J, Araujo L, Walton J, et al. Oxford screening programme for abdominal aortic aneurysm in men aged 65 to 74 years. Lancet. Sep. 10. 1988;2(8611):613-5. KQ1E4a. [pmid: 2900988].
23 Collin J, Heather B, Walton J. Growth rates of subclinical abdominal aortic aneurysms--implications for review and rescreening programmes. Eur J Vasc Surg. Apr. 1991;5(2):141-4. KQ2E5. [pmid: 2037085].
24 Conway AM, Malkawi AH, Hinchliffe RJ, et al. First-year results of a national abdominal aortic aneurysm screening programme in a single centre. Br J Surg. Jan. 2012;99(1):73-7. KQ1E5. [pmid: 21928466].
25 Cook TA, Galland RB. A prospective study to define the optimum rescreening interval for small abdominal aortic aneurysm. Cardiovasc Surg. Aug. 1996;4(4):441-4. KQ2E10. [pmid: 8866077].
26 Coughlin PA, Jackson D, White AD, et al. Meta-analysis of prospective trials determining the short- and mid-term effect of elective open and endovascular repair of abdominal aortic aneurysms on quality of life. Br J Surg. 2012. Dec. 19. KQ5E10. [pmid: 23254440].
27 Couto E, Duffy SW, Ashton HA, et al. Probabilities of progression of aortic aneurysms: estimates and implications for screening policy. J Med Screen. 2002;9(1):40-2. KQ2E5. [pmid: 11943797].
28 Dangas G, O'Connor D, Firwana B, et al. Open versus endovascular stent graft repair of abdominal aortic aneurysms: a meta-analysis of randomized trials. Jacc: Cardiovascular Interventions. Oct. 2012;5(10):1071-80. KQ5E10. [pmid: 23078738].
29 Dawson JA, Choke E, Loftus IM, et al. A randomised placebo-controlled double-blind trial to evaluate lipid-lowering pharmacotherapy on proteolysis and inflammation in abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Jan. 2011;41(1):28-35. KQ4E5. [pmid: 20880729].
30 De Rango P, Cao P, Parlani G, et al. Outcome after endografting in small and large abdominal aortic aneurysms: a metanalysis. Eur J Vasc Endovasc Surg. Feb. 2008;35(2):162-72. KQ4E9. [pmid: 18069023].
31 De Rango P, Verzini F, Parlani G, et al. Quality of life in patients with small abdominal aortic aneurysm: the effect of early endovascular repair versus surveillance in the CAESAR trial. Eur J Vasc Endovasc Surg. Mar. 2011;41(3):324-31. KQ4E5. [pmid: 21145269].
32 Derubertis BG, Trocciola SM, Ryer EJ, et al. Abdominal aortic aneurysm in women: prevalence, risk factors, and implications for screening. J Vasc Surg. Oct. 2007;46(4):630-5. KQ1E5. [pmid: 17903646].
33 Dodd BR, Spence RA. Doxycycline inhibition of abdominal aortic aneurysm growth: a systematic review of the literature. Curr Vasc Pharmacol. Jul. 1. 2011;9(4):471-8. KQ4E8. [pmid: 21595625].
34 Dubois L, Novick TV, Harris JR, et al. Outcomes after endovascular abdominal aortic aneurysm repair are equivalent between genders despite anatomic differences in women. Journal of Vascular Surgery. Feb. 2013;57(2):382-9. KQ5E10. [pmid: 23266281].
35 Duncan JL, Wolf B, Nichols DM, et al. Screening for abdominal aortic aneurysm in a geographically isolated area. Br J Surg. Aug. 2005;92(8):984-8. KQ1E5. [pmid: 16034847].
36 Duncan JL, Harrild KA, Iversen L, et al. Long term outcomes in men screened for abdominal aortic aneurysm: prospective cohort study. BMJ. 2012;344:e2958. KQ2E4a. [pmid: 22563092].
37 Dunne JA, Bailey MA, Griffin KJ, et al. Statins: The Holy Grail of Abdominal Aortic Aneurysm (AAA) Growth Attenuation? A Systematic Review of the Literature. Curr Vasc Pharmacol. 2012. Jun. 22. KQ3E8. [pmid: 22724473].
38 Dynda DI, Andrews JA, Chiou AC, et al. Project PROMIS: Peoria Regional Outpatient Medical Imaging Study. Am J Surg. 2008;195(3):322-7. KQ1E3. [pmid: 18308039].
39 Fassiadis N, Roidl M, Stannett H, et al. Is screening of abdominal aortic aneurysm effective in a general practice setting?. Int Angiol. Jun. 2005;24(2):185-8. KQ1E5. [pmid: 15997221].
40 Ferguson CD, Clancy P, Bourke B, et al. Association of statin prescription with small abdominal aortic aneurysm progression. Am Heart J. Feb. 2010;159(2):307-13. KQ2E5. [pmid: 20152231].
41 Filardo G, Powell JT, Martinez MA, et al. Surgery for small asymptomatic abdominal aortic aneurysms. [Review][Update of Cochrane Database Syst Rev. 2008;(4):CD001835; PMID: 18843626]. Cochrane Database of Systematic Reviews. 2012;3:CD001835. KQ3E8. [pmid: 22419281].
42 Fleming C, Whitlock E, Beil T, et al. Primary care screening for abdominal aortic aneurysm. Evidence Synthesis Number 35. Rockville, MD. Agency for Healthcare Research and Quality. 2005. [pmid: 20722131]. KQ1E8.
43 Freiberg MS, Arnold AM, Newman AB, et al. Abdominal aortic aneurysms, increasing infrarenal aortic diameter, and risk of total mortality and incident cardiovascular disease events: 10-year follow-up data from the Cardiovascular Health Study. Circulation. Feb. 26. 2008;117(8):1010-7. KQ2E5. [pmid: 18268154].
44 Gadowski GR, Pilcher DB, Ricci MA. Abdominal aortic aneurysm expansion rate: effect of size and beta-adrenergic blockade. J Vasc Surg. Apr. 1994;19(4):727-31. KQ4E4a. [pmid: 7909340].
45 Gibbs DM, Bown MJ, Hussey G, et al. The ectatic aorta: no benefit in surveillance. Annals of Vascular Surgery. Oct. 2010;24(7):908-11. KQ2E7a. [pmid: 20471205].
46 Golledge J, Muller R, Clancy P, et al. Evaluation of the diagnostic and prognostic value of plasma D-dimer for abdominal aortic aneurysm. Eur Heart J. Feb. 2011;32(3):354-64. KQ2E5. [pmid: 20530504].
47 Golledge J, Norman PE. Current status of medical management for abdominal aortic aneurysm. Atherosclerosis. Jul. 2011;217(1):57-63. KQ4E8. [pmid: 21596379].
48 Greco G, Egorova NN, Gelijns AC, et al. Development of a novel scoring tool for the identification of large >/=5 cm abdominal aortic aneurysms. Ann Surg. Oct. 2010;252(4):675-82. KQ2E5. [pmid: 20881774].
49 Grimshaw GM, Thompson JM, Hamer JD. Prevalence of abdominal aortic aneurysm associated with hypertension in an urban population. J Med Screen. Oct. 1994;1(4):226-8. KQ1E5. [pmid: 8790525].
50 Guessous I, Periard D, Lorenzetti D, et al. The efficacy of pharmacotherapy for decreasing the expansion rate of abdominal aortic aneurysms: a systematic review and meta-analysis. PLoS One. 2008;3(3):e1895. KQ4E8. [pmid: 18365027].
51 Hobbs S, Claridge M, Drage M, et al. Strategies to improve the effectiveness of abdominal aortic aneurysm screening programmes. J Med Screen. 2004;11(2):93-6. KQ2E2. [pmid: 15153325].
52 Huber TS, Wang JG, Derrow AE, et al. Experience in the United States with intact abdominal aortic aneurysm repair. J Vasc Surg. Feb. 2001;33(2):304-10. KQ5E9. [pmid: 11174782].
53 Hupp JA, Martin JD, Hansen LO. Results of a single center vascular screening and education program. J Vasc Surg. 2007;46(2):182-7. KQ1E5. [pmid: 17664093].
54 Jackson RS, Chang DC, Freischlag JA. Comparison of long-term survival after open vs endovascular repair of intact abdominal aortic aneurysm among Medicare beneficiaries. JAMA. Apr. 18. 2012;307(15):1621-8. KQ3E10, KQ5E10. [pmid: 22511690].
55 Jamrozik K, Norman PE, Spencer CA, et al. Screening for abdominal aortic aneurysm: lessons from a population-based study. Med J Aust. Oct. 2. 2000;173(7):345-50. KQ1E5. [pmid: 11062788].
56 Kanagasabay R, Gajraj H, Pointon L, et al. Co-morbidity in patients with abdominal aortic aneurysm. J Med Screen. 1996;4(4):208-10. KQ1E5. [pmid: 9041487].
57 Karlsson L, Bergqvist D, Lindback J, et al. Expansion of small-diameter abdominal aortic aneurysms is not reflected by the release of inflammatory mediators IL-6, MMP-9 and CRP in plasma. Eur J Vasc Endovasc Surg. Apr. 2009;37(4):420-4. KQ4E5. [pmid: 19119028].
58 Keeling WB, Armstrong PA, Stone PA, et al. An overview of matrix metalloproteinases in the pathogenesis and treatment of abdominal aortic aneurysms. Vasc Endovascular Surg. Nov. 2005;39(6):457-64. KQ2E5. [pmid: 16382266].
59 Kent KC, Zwolak RM, Egorova NN, et al. Analysis of risk factors for abdominal aortic aneurysm in a cohort of more than 3 million individuals. J Vasc Surg. Sep. 2010;52(3):539-48. KQ2E5. [pmid: 20630687].
60 Khaira HS, Herbert LM, Crowson MC. Screening for abdominal aortic aneurysms does not increase psychological morbidity. Ann R Coll Surg Engl. Sep. 1998;80(5):341-2. KQ3E4a. [pmid: 9849335].
61 Kim LG, Thompson SG, Marteau TM, et al. Screening for abdominal aortic aneurysms: the effects of age and social deprivation on screening uptake, prevalence and attendance at follow-up in the MASS trial. J Med Screen. 2004;11(1):50-3. KQ1E5. [pmid: 15006116].
62 Koning GG, Vallabhneni SR, Van Marrewijk CJ, et al. Procedure-related mortality of endovascular abdominal aortic aneurysm repair using revised reporting standards. Rev Bras Cir Cardiovasc. Apr. 13. 2007;22(1):7-13. KQ5E10. [pmid: 17992299].
63 Koo V, Lau L, McKinley A, et al. Pilot study of sexual dysfunction following abdominal aortic aneurysm surgery. J Sex Med. Jul. 2007;4(4:Pt 2):t-52. KQ5E10. [pmid: 17081220].
64 Krohn CD, Kullmann G, Kvernebo K, et al. Ultrasonographic screening for abdominal aortic aneurysm. Eur J Surg. Oct. 1992;158(10):527-30. KQ1E4a. [pmid: 1360823].
65 Lall P, Gloviczki P, Agarwal G, et al. Comparison of EVAR and open repair in patients with small abdominal aortic aneurysms: can we predict results of the PIVOTAL trial?. J Vasc Surg. Jan. 2009;49(1):52-9. KQ4E4, KQ5E4. [pmid: 19174250].
66 Laughlin GA, Allison MA, Jensky NE, et al. Abdominal aortic diameter and vascular atherosclerosis: the Multi-Ethnic Study of Atherosclerosis. Eur J Vasc Endovasc Surg. Apr. 2011;41(4):481-7. KQ1E5. [pmid: 21236707].
67 Laws C, Eastman J. Screening for abdominal aortic aneurysm by general practitioners and practice-based ultrasonographers. J Med Screen. 2006;13(3):160-1. KQ1E5. [pmid: 17007659].
68 Leach SD, Toole AL, Stern H, et al. Effect of beta-adrenergic blockade on the growth rate of abdominal aortic aneurysms. Arch Surg. May. 1988;123(5):606-9. KQ4E4a. [pmid: 2895995].
69 LeCroy CJ, Passman MA, Taylor SM, et al. Should endovascular repair be used for small abdominal aortic aneurysms?. Vasc Endovascular Surg. 2008;42(2):113-9. KQ5E4a. [pmid: 18270271].
70 Lederle FA, Johnson GR, Wilson SE, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. Mar. 15. 1997;126(6):441-9. KQ4E4a. [pmid: 9072929].
71 Lederle FA, Johnson GR, Wilson SE, et al. The aneurysm detection and management study screening program: validation cohort and final results. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. May. 22. 2000;160(10):1425-30. KQ4E4a. [pmid: 10826454].
72 Lederle FA, Johnson GR, Wilson SE, et al. Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm. J Vasc Surg. Oct. 2003;38(4):745-52. KQ4E5, KQ5E5. [pmid: 14560224].
73 Lederle FA. Ultrasonographic screening for abdominal aortic aneurysms. Ann Intern Med. Sep. 16. 2003;139(6):516-22. KQ3E8. [pmid: 13679330].
74 Lederle FA, Nelson DB, Joseph AM. Smokers' relative risk for aortic aneurysm compared with other smoking-related diseases: a systematic review. J Vasc Surg. Aug. 2003;38(2):329-34. KQ1E5. [pmid: 12891116].
75 Lee AJ, Fowkes FG, Carson MN, et al. Smoking, atherosclerosis and risk of abdominal aortic aneurysm. Eur Heart J. Apr. 1997;18(4):671-6. KQ1E5. [pmid: 9129900].
76 Lee ES, Pickett E, Hedayati N, et al. Implementation of an aortic screening program in clinical practice: implications for the Screen For Abdominal Aortic Aneurysms Very Efficiently (SAAAVE) Act. J Vasc Surg. May. 2009;49(5):1107-11. KQ1E5. [pmid: 19307082].
77 Leurs LJ, Buth J, Laheij RJ. Long-term results of endovascular abdominal aortic aneurysm treatment with the first generation of commercially available stent grafts. Arch Surg. Jan. 2007;142(1):33v-41. KQ5E9. [pmid: 17224498].
78 Lindeman JH, Abdul-Hussien H, Van Bockel JH, et al. Clinical trial of doxycycline for matrix metalloproteinase-9 inhibition in patients with an abdominal aneurysm: doxycycline selectively depletes aortic wall neutrophils and cytotoxic T cells. Circulation. Apr. 28. 2009;119(16):2209-16. KQ4E5. [pmid: 19364980].
79 Lindholt JS, Henneberg EW, Fasting H, et al. Hospital based screening of 65-73 year old men for abdominal aortic aneurysms in the county of Viborg, Denmark. J Med Screen. 1996;3(1):43-6. KQ1E5. [pmid: 8861051].
80 Lindholt JS, Henneberg EW, Fasting H, et al. Mass or high-risk screening for abdominal aortic aneurysm. Br J Surg. Jan. 1997;84(1):40-2. KQ1E5. [pmid: 9043447].
81 Lindholt JS, Heegaard NH, Vammen S, et al. Smoking, but not lipids, lipoprotein(a) and antibodies against oxidised LDL, is correlated to the expansion of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Jan. 2001;21(1):51-6. KQ4E4a. [pmid: 11170878].
82 Lindholt JS. Relatively high pulmonary and cardiovascular mortality rates in screening-detected aneurysmal patients without previous hospital admissions. Eur J Vasc Endovasc Surg. Jan. 2007;33(1):94-9. KQ3E5. [pmid: 16893664].
83 Lindholt JS, Norman P. Screening for abdominal aortic aneurysm reduces overall mortality in men. A meta-analysis of the mid- and long-term effects of screening for abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Aug. 2008;36(2):167-71. KQ1E4. [pmid: 18485756].
84 Lindholt JS, Sorensen HT, Michel JB, et al. Low-dose aspirin may prevent growth and later surgical repair of medium-sized abdominal aortic aneurysms. Vasc Endovascular Surg. Aug. 2008;42(4):329-34. KQ4E4a. [pmid: 18728038].
85 Lindholt JS, Norman PE. Meta-analysis of postoperative mortality after elective repair of abdominal aortic aneurysms detected by screening. Br J Surg. May. 2011;98(5):619-22. KQ5E10. [pmid: 21374589].
86 Lindsay SM, Duncan JL, Cairns J, et al. Geography, private costs and uptake of screening for abdominal aortic aneurysm in a remote rural area. BMC Public Health. 2006;6:80. KQ1E5. [pmid: 16571121].
87 MacSweeney ST, Ellis M, Worrell PC, et al. Smoking and growth rate of small abdominal aortic aneurysms. Lancet. Sep. 3. 1994;344(8923):651-2. KQ2E5. [pmid: 7915350].
88 Mani K, Alund M, Bjorck M, et al. Screening for abdominal aortic aneurysm among patients referred to the vascular laboratory is cost-effective. Eur J Vasc Endovasc Surg. Feb. 2010;39(2):208-16. KQ1E2. [pmid: 19942460].
89 Marteau TM. Psychological costs of screening. BMJ. Aug. 26. 1989;299(6698):527. KQ3E4a. [pmid: 2507059].
90 Marteau TM, Kim LG, Upton J, et al. Poorer self assessed health in a prospective study of men with screen detected abdominal aortic aneurysm: a predictor or a consequence of screening outcome?. J Epidemiol Community Health. Dec. 2004;58(12):1042-6. KQ3E5. [pmid: 15547070].
91 Mastracci TM, Cina CS. Screening for abdominal aortic aneurysm in Canada: review and position statement of the Canadian Society for Vascular Surgery. J Vasc Surg. Jun. 2007;45(6):1268-76. KQ1E8. [pmid: 17543696].
92 McCollum P. Comments regarding ‘Implications of attendance patterns in Northern Ireland for abdominal aortic aneurysm screening’. Eur J Vasc Endovasc Surg. Oct. 2011;42(4):440-1. KQ1E4. [pmid: 21741281].
93 Mell M, White JJ, Hill BB, et al. No increased mortality with early aortic aneurysm disease. Journal of Vascular Surgery. Nov. 2012;56(5):1246-51. KQ1aE4a. [pmid: 22832264].
94 Morris GE, Hubbard CS, Quick CR. An abdominal aortic aneurysm screening programme for all males over the age of 50 years. Eur J Vasc Surg. Mar. 1994;8(2):156-60. KQ2E5. [pmid: 8181607].
95 Mouawad NJ, Leichtle SW, Manchio JV, et al. Construct domain analysis of patient health-related quality of life: physical and mental trajectory profiles following open versus endovascular repair of abdominal aortic aneurysm. Patient Related Outcome Measures. 2013;4:1-6. KQ5E10. [pmid: 23300352].
96 Muehling BM, Halter G, Lang G, et al. Prospective randomized controlled trial to evaluate “fast-track” elective open infrarenal aneurysm repair. Langenbecks Arch Surg. May. 2008;393(3):281-7. KQ4E9. [pmid: 18273636].
97 Nicholls EA, Norman PE, Lawrence-Brown MM, et al. Screening for abdominal aortic aneurysms in Western Australia. Aust N Z J Surg. Nov. 1992;62(11):858-61. KQ1E5. [pmid: 20169703].
98 Norman PE, Jamrozik K, Lawrence BM, et al. Results of the Western Australian trial of screening for abdominal aortic aneurysms. ANZ J Surg. 2005;75:A116. PMID: None. KQ1E8.
99 Norman PE, Jamrozik K, Lawrence-Brown MM, et al. Population based randomised controlled trial on impact of screening on mortality from abdominal aortic aneurysm. BMJ. Nov. 27. 2004;329(7477):1259. KQ1I1, KQ3I1. [pmid: 15545293].
100 O'Kelly TJ, Heather BP. General practice-based population screening for abdominal aortic aneurysms: a pilot study. Br J Surg. May. 1989;76(5):479-80. KQ1E4a. [pmid: 2660948].
101 Ogren M, Bengtsson H, Bergqvist D, et al. Prognosis in elderly men with screening-detected abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. Jan. 1996;11(1):42-7. KQ1E4a. [pmid: 8564486].
102 Ouriel K. Randomized clinical trials of endovascular repair versus surveillance for treatment of small abdominal aortic aneurysms. J Endovasc Ther. Feb. Suppl 1. 2009;16:I94-105. KQ4E8. [pmid: 19317579].
103 Padberg FT Jr., Hauck K, Mercer RG, et al. Screening for abdominal aortic aneurysm with electronic clinical reminders. Am J Surg. Nov. 2009;198(5):670-4. KQ1E5. [pmid: 19887197].
104 PALOMBO D, LUCERTINI G, PANE B, et al. District-based abdominal aortic aneurysm screening in population aged 65 years and older. J Cardiovasc Surg. Dec. 2010;51(6):777-82. KQ1E5. [pmid: 21124273].
105 Patel MS, Brown DA, Wilson SE. Relevance of the ADAM and UK Small Aneurysm trial data in the age of endovascular aneurysm repair. Arch Surg. Sep. 2009;144(9):806-10. KQ4E4a. [pmid: 19797103].
106 Peach G, Holt P, Loftus I, et al. Questions remain about quality of life after abdominal aortic aneurysm repair. [Review]. Journal of Vascular Surgery. Aug. 2012;56(2):520-7. KQ5E10. [pmid: 22840902].
107 Powell JT. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. May. 9. 2002;346(19):1445-52. KQ5E5. [pmid: 12000814].
108 Powell JT, Greenhalgh RM. Clinical practice. Small abdominal aortic aneurysms. N Engl J Med. May. 8. 2003;348(19):1895-901. KQ2E4. [pmid: 12736283].
109 Prinssen M, Buskens E, Blankensteijn JD, et al. Quality of life endovascular and open AAA repair. Results of a randomised trial. Eur J Vasc Endovasc Surg. Feb. 2004;27(2):121-7. KQ5E10. [pmid: 14718892].
110 Raval MV, Eskandari MK. Outcomes of elective abdominal aortic aneurysm repair among the elderly: endovascular versus open repair. Surgery. Feb. 2012;151(2):245-60. KQ5E10. [pmid: 21244863].
111 Rothberg AD, McLeod H, Walters L, et al. Screening for abdominal aortic aneurysm--a pilot study in six medical schemes. S Afr Med J. Jan. 2007;97(1):58-62. KQ1E5. [pmid: 17378284].
112 Rughani G, Robertson L, Clarke M. Medical treatment for small abdominal aortic aneurysms. Cochrane Database Syst Rev. 2012;(9):CD009536. PMID: None. KQ4E5, KQ5E5. [pmid: 22972146].
113 Salem MK, Rayt HS, Hussey G, et al. Should Asian men be included in abdominal aortic aneurysm screening programmes?. Eur J Vasc Endovasc Surg. Dec. 2009;38(6):748-9. KQ1E5. [pmid: 19666232].
114 Sampaio SM, Shin SH, Panneton JM, et al. Intraoperative endoleak during EVAR: frequency, nature, and significance. Vasc Endovascular Surg. Aug. 2009;43(4):352-9. KQ5E9. [pmid: 19351648].
115 Schermerhorn M, Zwolak R, Velazquez O, et al. Ultrasound screening for abdominal aortic aneurysm in medicare beneficiaries. Ann Vasc Surg. Jan. 2008;22(1):16-24. KQ1E5. [pmid: 18055170].
116 Schlosser FJ, Tangelder MJ, Verhagen HJ, et al. Growth predictors and prognosis of small abdominal aortic aneurysms. J Vasc Surg. Jun. 2008;47(6):1127-33. KQ2E2, KQ5E5. [pmid: 18440183].
117 Schlosser FJ, Vaartjes I, van der Heijden GJ, et al. Mortality after elective abdominal aortic aneurysm repair. Ann Surg. Jan. 2010;251(1):158-64. KQ5E10. [pmid: 19838103].
118 Schmidt T, Muhlberger N, Chemelli-Steingruber IE, et al. Benefit, risks and cost-effectiveness of screening for abdominal aortic aneurysm. Rofo. Jul. 2010;182(7):573-80. KQ1E4. [pmid: 20563953].
119 Schouten O, van Laanen JH, Boersma E, et al. Statins are associated with a reduced infrarenal abdominal aortic aneurysm growth. Eur J Vasc Endovasc Surg. Jul. 2006;32(1):21-6. KQ4E4a. [pmid: 16520071].
120 Scott RA, Kim LG, Ashton HA, et al. Assessment of the criteria for elective surgery in screen-detected abdominal aortic aneurysms. J Med Screen. 2005;12(3):150-4. KQ2E5. [pmid: 16156946].
121 Simoni G, Pastorino C, Perrone R, et al. Screening for abdominal aortic aneurysms and associated risk factors in a general population. Eur J Vasc Endovasc Surg. Aug. 1995;10(2):207-10. KQ1E5. [pmid: 7655973].
122 Simoni G, Gianotti A, Ardia A, et al. Screening study of abdominal aortic aneurysm in a general population: lipid parameters. Cardiovasc Surg. Aug. 1996;4(4):445-8. KQ1E5. [pmid: 8866078].
123 Singh K, Bonaa KH, Jacobsen BK, et al. Prevalence of and risk factors for abdominal aortic aneurysms in a population-based study : The Tromso Study. Am J Epidemiol. Aug. 1. 2001;154(3):236-44. KQ1E10. [pmid: 11479188].
124 Smith FC, Grimshaw GM, Paterson IS, et al. Ultrasonographic screening for abdominal aortic aneurysm in an urban community. Br J Surg. Nov. 1993;80(11):1406-9. KQ1E5. [pmid: 8252350].
125 Spencer CA, Jamrozik K, Norman PE, et al. The potential for a selective screening strategy for abdominal aortic aneurysm. J Med Screen. 2000;7(4):209-11. KQ1E5. [pmid: 11202589].
126 Sukhija R, Aronow WS, Sandhu R, et al. Mortality and size of abdominal aortic aneurysm at long-term follow-up of patients not treated surgically and treated with and without statins. Am J Cardiol. Jan. 15. 2006;97(2):279-80. KQ4E4a. [pmid: 16442379].
127 Svensjo S, Bjorck M, Gurtelschmid M, et al. Low prevalence of abdominal aortic aneurysm among 65-year-old Swedish men indicates a change in the epidemiology of the disease. Circulation. Sep. 6. 2011;124(10):1118-23. KQ1E5. [pmid: 21844079].
128 Sweeting MJ, Thompson SG. Making predictions from complex longitudinal data, with application to planning monitoring intervals in a national screening programme. J R Stat Soc Ser A Stat Soc. Apr. 2012;175(2):569-86. KQ2bE5. [pmid: 22879705].
129 Takagi H, Matsui M, Umemoto T. A meta-analysis of clinical studies of statins for prevention of abdominal aortic aneurysm expansion. J Vasc Surg. Dec. 2010;52(6):1675-81. KQ4E4a. [pmid: 20638223].
130 Takagi H, Umemoto T. Reply to ‘Comment on Effects of Statin Therapy on Abdominal Aortic Aneurysm Growth: A Meta-analysis and Meta-regression of Observational Comparative Studies’. European Journal of Vascular & Endovascular Surgery. Jan. 2013;45(1):98-9. KQ3E4a. [pmid: 23116985].
131 Takagi H, Goto SN, Matsui M, et al. A further meta-analysis of population-based screening for abdominal aortic aneurysm. J Vasc Surg. Oct. 2010;52(4):1103-8. KQ1E8. [pmid: 20541347].
132 Thomas SM, Beard JD, Ireland M, et al. Results from the prospective registry of endovascular treatment of abdominal aortic aneurysms (RETA): mid term results to five years. Eur J Vasc Endovasc Surg. Jun. 2005;29(6):563-70. KQ5E10. [pmid: 15878530].
133 Thompson AR, Cooper JA, Ashton HA, et al. Growth rates of small abdominal aortic aneurysms correlate with clinical events. Br J Surg. Jan. 2010;97(1):37-44. KQ2E10. [pmid: 20013940].
134 Twine CP, Williams IM. Systematic review and meta-analysis of the effects of statin therapy on abdominal aortic aneurysms. Br J Surg. Mar. 2011;98(3):346-53. KQ4E4a. [pmid: 21254006].
135 Twine CP, Williams IM. Authors' reply: Systematic review and meta-analysis of the effects of statin therapy on abdominal aortic aneurysms. (Br J Surg 2011; 98: 362-353). Br J Surg. May. 2011;98(5):745. KQ4E4a. [pmid: 21462180].
136 United Kingdom Small Aneurysm Trial Participants. Smoking, lung function and the prognosis of abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):636-42. KQ4E5. [pmid: 10873733].
137 van Lindert NH, Bienfait HP, Gratama JW, et al. Screening for aneurysm of the abdominal aorta: prevalence in patients with stroke or TIA. Eur J Neurol. May. 2009;16(5):602-7. KQ1E3. [pmid: 19236464].
138 Vardulaki KA, Prevost TC, Walker NM, et al. Growth rates and risk of rupture of abdominal aortic aneurysms. Br J Surg. Dec. 1998;85(12):1674-80. KQ2E5. [pmid: 9876073].
139 Vardulaki KA, Walker NM, Day NE, et al. Quantifying the risks of hypertension, age, sex and smoking in patients with abdominal aortic aneurysm. Br J Surg. Feb. 2000;87(2):195-200. KQ1E5. [pmid: 10671927].
140 Veroux P, D'Arrigo G, Veroux M, et al. Sexual dysfunction after elective endovascular or hand-assisted laparoscopic abdominal aneurysm repair. Eur J Vasc Endovasc Surg. Jul. 2010;40(1):71-5. KQ5E4b. [pmid: 20403714].
141 Vogel TR, Symons RG, Flum DR. Longitudinal outcomes after endovascular repair of abdominal aortic aneurysms. Vasc Endovascular Surg. Oct. 2008;42(5):412-9. KQ5E10. [pmid: 18583307].
142 Walton LJ, Franklin IJ, Bayston T, et al. Inhibition of prostaglandin E2 synthesis in abdominal aortic aneurysms: implications for smooth muscle cell viability, inflammatory processes, and the expansion of abdominal aortic aneurysms. Circulation. Jul. 6. 1999;100(1):48-54. KQ4E4a. [pmid: 10393680].
143 Wang GJ, Carpenter JP. EVAR in small versus large aneurysms: does size influence outcome?. Vasc Endovascular Surg. Jun. 2009;43(3):244-51. KQ5E4a. [pmid: 19088132].
144 Wanhainen A, Bergqvist D, Boman K, et al. Risk factors associated with abdominal aortic aneurysm: a population-based study with historical and current data. J Vasc Surg. Mar. 2005;41(3):390-6. KQ1E5. [pmid: 15838468].
145 Wilmink AB, Hubbard CS, Day NE, et al. Effect of propanolol on the expansion of abdominal aortic aneurysms: a randomized study. Br J Surg. 2000;87:499. KQ4E4a.
146 Wilmink AB, Hubbard CS, Day NE, et al. The incidence of small abdominal aortic aneurysms and the change in normal infrarenal aortic diameter: implications for screening. Eur J Vasc Endovasc Surg. Feb. 2001;21(2):165-70. KQ2E5. [pmid: 11237791].
147 Wilmink AB, Vardulaki KA, Hubbard CS, et al. Are antihypertensive drugs associated with abdominal aortic aneurysms?. J Vasc Surg. Oct. 2002;36(4):751-7. KQ4E4a. [pmid: 12368736].
148 Wilmink T, Claridge MW, Fries A, et al. A comparison between the short term and long term benefits of screening for abdominal aortic aneurysms from the Huntingdon Aneurysm screening programme. Eur J Vasc Endovasc Surg. Jul. 2006;32(1):16-20. KQ1E4. [pmid: 16466938].
149 Wilmink TB, Quick CR, Hubbard CS, et al. The influence of screening on the incidence of ruptured abdominal aortic aneurysms. J Vasc Surg. Aug. 1999;30(2):203-8. KQ1E5, KQ2E5. [pmid: 10436439].
150 Zarins CK, Crabtree T, Arko FR, et al. Endovascular repair or surveillance of patients with small AAA. Eur J Vasc Endovasc Surg. 2005;29(5):496-503. KQ4E4, KQ5E4. [pmid: 15966088].
151 Zarins CK, Crabtree T, Bloch DA, et al. Endovascular aneurysm repair at 5 years: Does aneurysm diameter predict outcome?. J Vasc Surg. 2006;44(5):920-9. KQ4E4, KQ5E4. [pmid: 17098519].