# Ongoing Studies and Trials Pending Assessment

Appendix C Table 1 Ongoing Studies and Trials Pending Assessment

Investigator, study name | Location | Number of participants | Intervention | Outcomes | 2013 Status
AARDVARK (Evaluation of Effect of Angiotensin-Converting Enzyme [ACE] Inhibitors on Small Aneurysm Growth Rate) | Imperial College London | 225 | Drug: perindopril arginine (10 mg per day) Drug: amlodipine (5 mg per day) Drug: placebo | Primary: AAA growth rate of small aneurysms (3.5–4.9 cm) measured by CTA Secondary: AAA-related mortality | Pending: Currently recruiting participants Estimated study completion date: October 2014
Grondal VIVA | Central Denmark | 50,000 men | Combination AAA, PAD, and HTN screening | Primary: All-cause mortality Secondary: AAA-related mortality, AAA progression, cost, QOL | Recruitment: 2008–2010 Results pending: 3-, 5-, 10-, and 15-year followup
Smiseth | Oslo | 1,500 men | Annual screening for AAA and PAD using ultrasound and AAI | Primary: AAA incidence (≥3.0 cm) Secondary: PAD incidence (measured by AAI) | Recruitment: Began January 2011 Estimated study completion date: December 2029
Dalman Study of the Effectiveness of Telmisartan in Slowing the Progression of Abdominal Aortic Aneurysms (TEDY) | U.S. | 40 | Drug: telmisartan (40 mg once a day) Drug: placebo | Primary: AAA growth rate of small aneurysms (3.5–4.9 cm) measured by CTA Secondary: Change in circulating AAA-biomarkers, QOL | Recruitment: Began September 2012 Estimated study completion date: August 2015
Sillesen CRD007 for the Treatment of Abdominal Aorta Aneurysm (AORTA Trial) | Denmark, Sweden, U.K. | NR | Drug: 3 dose levels of CRD007: 10, 25, and 40 mg Drug: placebo | NR | Study is completed: “no details reported”
Blankensteijn Study on Anti-inflammatory Effect of Anti-Hypertensive Treatment in Patients With Small AAA and Mild Hypertension (PISA) | The Netherlands | 12 | Drug: aliskiren (150–300 mg per day) Drug: amlodipine (5–10 mg per day) | Primary: change in aneurysmal vessel wall inflammation measured by PET-CT Secondary: AAA growth rate, change in large vessel inflammation | Recruitment: Began September 2011 Estimated study completion date: September 2013
Non-Invasive Treatment of Abdominal Aortic Aneurysm Clinical Trial | US | 248 | Drug: doxycycline (100 mg, twice a day) Drug: placebo | Primary: AAA growth rate measured by CT Secondary: Change in circulating AAA biomarkers | Recruitment: Began January 2013 Estimated study completion date: June 2017
Saiki | Japan | 40 | Drug: telmisartan (dose NR) Drug: placebo | Primary: AAA-growth rate | Recruitment: Began March 2010 Estimated study completion date: NR