# Search Strategy and Literature Flow Diagram

## Screening for abdominal aortic aneurysm

Search strategies (updated 1/31/2013)

Databases searched:

MEDLINE

PubMed

Cochrane Central Register of Controlled Trials

Cochrane Database of Systematic Reviews

Database of Abstracts of Reviews of Effects

Key
- / = MeSH subject heading
- * = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- sb = subset

## MEDLINE: screening

Ovid MEDLINE(R), Ovid MEDLINE(R) Daily Update

1. Aortic Aneurysm, Abdominal/
2. abdominal aortic aneurysm*.ti,ab.
3. 1 or 2
4. Mass Screening/
5. Screen*.ti,ab.
6. 4 or 5
7. 3 and 6
8. limit 7 to (english language and yr=“2004 -Current”)

## MEDLINE: clinical trials

Ovid MEDLINE(R), Ovid MEDLINE(R) Daily Update

1. Aortic Aneurysm, Abdominal/
2. abdominal aortic aneurysm*.ti,ab.
3. 1 or 2
4. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
5. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
6. random*.ti,ab.
7. control groups/ or double-blind method/ or single-blind method/
8. clinical trial*.ti,ab.
9. controlled trial*.ti,ab.
10. 4 or 5 or 6 or 7 or 8 or 9
11. 3 and 10

limit 11 to (english language and yr=“2004 -Current”)

## MEDLINE: treatment cohort studies

Ovid MEDLINE(R), Ovid MEDLINE(R) Daily Update

1. Aortic Aneurysm, Abdominal/co, dt, mo, pc, px, rh, su, th [Complications, Drug Therapy, Mortality, Prevention & Control, Psychology, Rehabilitation, Surgery, Therapy]
2. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
3. cohort*.ti,ab.
4. 2 or 3
5. 1 and 4
6. limit 5 to (english language and yr=“2004 -Current”)

## MEDLINE: all key questions

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations

1. abdominal aortic aneurysm*.ti,ab.
2. screen*.ti,ab.
3. random*.ti,ab.
4. clinical trial*.ti,ab.
5. controlled trial*.ti,ab.
6. cohort*.ti,ab.
7. longitudinal*.ti,ab.
8. follow up.ti,ab.
9. prospective*.ti,ab.
10. retrospective*.ti,ab.
11. meta analys*.ti,ab.
12. metaanalys*.ti,ab.
13. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. 1 and 13
15. limit 14 to (english language and yr=“2004 -Current”)

## PubMed: all key questions, publisher-supplied non-indexed citations only

#1 “abdominal aortic aneurysm” OR “abdominal aortic aneurysms”
#2 #1 AND publisher[sb]
#3 screen*[tiab] OR trial[tiab] OR trials[tiab] OR random*[tiab] OR cohort*[tiab] OR longitudinal*[tiab] OR “follow up”[tiab] OR “followed up”[tiab] OR followup*[tiab] OR prospective*[tiab] OR retrospective*[tiab]
#4 #2 AND #3 Limits: English, Publication Date from 2004 to 3000

## PubMed: systematic reviews

#1 Aortic Aneurysm, Abdominal“[Mesh] AND systematic[sb]
#2 (“abdominal aortic aneurysm”[ti] OR “abdominal aortic aneurysms”[ti]) AND systematic[sb] AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb])
#3 #1 OR #2 English, Publication Date from 2004 to 3000

## Database of Abstracts of Reviews of Effects

(abdominal aortic aneurysm) OR (abdominal aortic aneurysms) IN DARE FROM 2004 TO 2013

## Cochrane Central Register of Controlled Trials

“abdominal aortic aneurysm” or “abdominal aortic aneurysms”, from 2004 to 2013 in Trials

Appendix B Figure 1 Literature Flow Diagram

Figure 4 is a flow chart that summarizes the search and selection of articles. There were 2,595 citations identified by searching MEDLINE, Pubmed, Cochrane Center Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Database of Abstracts of Reviews of Effects. An additional 128 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 2,723 unique citations were screened at the title/abstract stage. The full text of 204 citations were examined for inclusion for one or more of the five Key Questions. Twelve articles were included for Key Question 1, 11 for Key Question 2, 7 for Key Question 3, 21 for Key Question 4, and 17 for Key Question 5. Reasons for excluding the other articles are available in Appendix D.