# Detailed Methods

Appendix A Table 1 Inclusion/Exclusion Criteria

Category | Inclusion | Exclusion
Populations | One-time and repeated screening (KQs 1–3): Asymptomatic adult population Treatment of small AAA (KQs 4, 5): Asymptomatic adult population with small AAA (3.0–5.4 cm) | One-time and repeated screening (KQs 1–3): Patients experiencing symptoms related to AAA Treatment of Small AAA (KQs 4, 5): Patients experiencing symptoms related to AAA, populations with AAA >5.4 cm or <3.0 cm
Setting | Conducted in primary care or other setting with primary care–comparable population Countries applicable to U.S. (all countries listed as “very high” on the Human Development Index)
Disease/Condition | Abdominal aortic aneurysm (aortic diameter ≥3.0 cm)
Screening | Ultrasound | Physical examination, CT, MRI
Treatment/management interventions or exposure | One-time and repeated screening (KQs 1–3): General or targeted screening with ultrasound Targeted screening may include the following:; - Screening based on one or more risk factors; - Screening based on risk derived from prediction/prognostic modeling); Treatment of small AAA (KQs 4, 5): Pharmacotherapy (statins, ACEIs, beta-blockers, antibiotics), surgery (open and EVAR), surveillance | One-time screening (KQ 1): Repeat AAA screening Repeat screening (KQ 2): One-time AAA screening
Comparisons or nonexposure | One-time screening (KQ 1): No screening, comparison of different screening approaches Repeat screening (KQ 2): No screening or one-time AAA screening using ultrasound, different repeated screening approaches, or no comparison/nonexposure Treatment of small AAA (KQs 4, 5): Surveillance, usual care, or placebo | Comparative effectiveness of treatments (KQs 4, 5)
Outcomes | Effectiveness of one-time and repeated screening (KQs 1, 2): All-cause mortality, AAA-related mortality, AAA rupture rate, AAA incidence (KQ 2 only) Harms of screening (KQ 3): Anxiety from risk labeling, anxiety of mortality, false-positive screening-related procedure, operative mortality, surgical procedures, and quality of life Effectiveness of treatment of small AAA (KQ 4): AAA annual growth rate, all-cause mortality, AAA-related mortality, operative mortality, AAA rupture rate, and quality of life Harms of treatment of small AAA (KQ 5): Surgery:; - Operative mortality; - Cardiac and vascular complications (e.g., MI, heart failure, arrhythmia, and stroke); - Pulmonary complications (e.g., respiratory distress, pneumonia); - Renal complications (e.g., renal failure, renal vein fistula, impaired renal function postsurgery); - Nerve system complications (e.g., impairment of sexual function); - Gastrointestinal complications (e.g., aortoenteric fistulas); - Blood loss; - Infection (e.g., sepsis); - Readmission to hospital within 30 days; - Time for recovery; - EVAR-specific complications:; ○ Device migration; ○ Graft thrombosis (e.g., lower limb thrombosis); ○ Kinking of device; ○ Conversion to open surgery; ○ Reinterventions; ○ Endoleak (any type); Pharmacotherapy: Serious adverse events (e.g., cognitive loss, muscle breakdown, neuropathy, pancreatic and hepatic dysfunction, sexual dysfunction), discontinuation of treatment Surveillance: Anxiety from risk labeling, anxiety of mortality
Study Designs | Effectiveness of screening, one-time and repeated (KQs 1, 2): RCTs, CCTs, large cohort studies (n>1,000, KQ 2 only) Effectiveness of treatment of small AAA (KQ 4): RCTs, SERs Harms of screening or treatment (KQ 3, 5): RCTs, cohort studies, case-control studies (KQ 3), SERs, registries | Effectiveness of screening, one-time and repeated (KQs 1, 2): Case-control and cross-sectional studies, editorial, letter, nonsystematic review, opinion, cost studies Effectiveness of treatment of small AAA (KQ 4): Cohort and case-control study, cross-sectional study, editorial, letter, nonsystematic review, opinion, cost studies Harms of screening or treatment (KQs 3, 5): Case-control (KQ 5), editorial, letter, nonsystematic review, opinion, cost studies
Language | English only | NonEnglish languages
Quality | Fair- and good-quality studies | Poor-quality studies