# References

1 U.S. Preventive Services Task Force. Routine vitamin supplementation to prevent cancer and cardiovascular disease: recommendations and rationale. Ann Intern Med. 2003;139(1):51-5. [pmid: 12834319].
2 Otten JJ, Hellwig JP, Meyers LD, editors. Dietary Reference Intakes: The Essential Guide to Nutrient Requirements. Washington, DC. National Academies Press. 2006.
3 Institute of Medicine. Dietary Reference Intakes for Calcium, Phosphorous, Magnesium, Vitamin D, and Fluoride. Washington, DC. National Academy Press. 1997.
4 Institute of Medicine. Dietary Reference Intakes for Thiamin, Riboflavin, Niacin, Vitamin B6, Folate, Vitamin B12, Pantothenic Acide, Biotin, and Choline. Washington, DC. National Academies Press. 1998.
5 Institute of Medicine. Dietary reference Intakes for Vitamin C, Vitamin E, Selenium, and Carotenoids. Washington, DC. National Academies Press. 2000.
6 Institute of Medicine. Dietary Reference Intakes for Vitamin A, Vitamin K, Arsenic, Boron, Chromium, Copper, Iodine, Iron, Manganese, Molybdenum, Nickel, Silicon, Vanadium, and Zinc. Washington, DC. National Academies Press. 2001.
7 Institute of Medicine. Dietary Reference Intakes for Water, Potassium, Sodium, Chloride, and Sulfate. Washington, DC. National Academies Press. 2005.
8 Institute of Medicine. Dietary Reference Intakes for Calcium and Vitamin D. Washington, DC. National Academies Press. 2011.
9 Radimer K, Bindewald B, Hughes J, et al. Dietary supplement use by U.S. adults: data from the National Health and Nutrition Examination Survey, 1999-2000. Am J Epidemiol. 2004;160(4):339-49. [pmid: 15286019].
10 Bailey RL, Gahche JJ, Lentino CV, et al. Dietary supplement use in the United States, 2003-2006. J Nutr. 2011;141(2):261-6. [pmid: 21178089].
11 Gahche J, Bailey R, Burt V, et al. Dietary supplement use among U.S. adults has increased since NHANES III (1988-1994). NCHS Data Brief. 2011;(61):1-8. [pmid: 21592424].
12 Nutrition Business Journal. NBJ's Supplement Business Report: An Analysis of Markets, Trends, Competition and Strategy in the U.S. Dietary Supplement Industry. New York. Penton Media. 2011.
13 Dwyer J. Why Do Americans Use Dietary Supplements? Motivation for Dietary Supplement Use. American Dietetic Association Food and Nutrition Conference and Expo. Oct 24, 2005. St. Louis, MO.
14 Dickinson A, Boyon N, Shao A. Physicians and nurses use and recommend dietary supplements: report of a survey. Nutr J. 2009;8:29. [pmid: 19570197].
15 Dickinson A, Shao A, Boyon N, et al. Use of dietary supplements by cardiologists, dermatologists and orthopedists: report of a survey. Nutr J. 2011;10:20. [pmid: 21371318].
16 Dickinson A, Bonci L, Boyon N, et al. Dietitians use and recommend dietary supplements: report of a survey. Nutr J. 2012;11:14. [pmid: 22416673].
17 Go AS, Mozaffarian D, Roger VL, et al. Heart disease and stroke statistics—2013 update: a report from the American Heart Association. Circulation. 2013;127(1):e6-245. [pmid: 23239837].
18 Fang J, Shaw KM, Keenan NL. Prevalence of coronary heart disease: United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(40):1377-81. [pmid: 21993341].
19 Centers for Disease Control and Prevention. Leading Causes of Death. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.cdc.gov/nchs/fastats/lcod.htm/ on 7 October 2013.
20 Surveillance Epidemiology and End Results. Cancer Stat Fact Sheets. Bethesda, MD. National Cancer Institute. 2012. Accessed at http://seer.cancer.gov/statfacts on 7 October 2013.
21 Yusuf S, Hawken S, Ounpuu S, et al. Effect of potentially modifiable risk factors associated with myocardial infarction in 52 countries (the INTERHEART study): case-control study. Lancet. 2004;364(9438):937-52. [pmid: 15364185].
22 Geffken DF, Cushman M, Burke GL, et al. Association between physical activity and markers of inflammation in a healthy elderly population. Am J Epidemiol. 2001;153(3):242-50. [pmid: 11157411].
23 Libby P, Ridker PM, Hansson GK. Progress and challenges in translating the biology of atherosclerosis. Nature. 2011;473(7347):317-25. [pmid: 21593864].
24 Steinberg D, Parthasarathy S, Carew TE, et al. Beyond cholesterol. Modifications of low-density lipoprotein that increase its atherogenicity. N Engl J Med. 1989;320(14):915-24. [pmid: 2648148].
25 Loft S, Poulsen HE. Cancer risk and oxidative DNA damage in man. J Mol Med (Berl). 1996;74(6):297-312. [pmid: 8862511].
26 Davis CD, Uthus EO. DNA methylation, cancer susceptibility, and nutrient interactions. Exp Biol Med (Maywood). 2004;229(10):988-95. [pmid: 15522834].
27 Das PM, Singal R. DNA methylation and cancer. J Clin Oncol. 2004;22(22):4632-42. [pmid: 15542813].
28 Robinson K, editor. Homocysteine and Vascular Disease. Norwell, MA. Kluwer Academic Publishers. 2000.
29 Edgar RM, Stephen J, Roberto PB, et al. Meta-analysis of folic acid supplementation trials on risk of cardiovascular disease and risk interaction with baseline homocysteine levels. Am J Cardiology. 2010;106(517):527. [pmid: 20691310].
30 Spence JD, Stampfer MJ. Understanding the complexity of homocysteine lowering with vitamins: the potential role of subgroup analyses. JAMA. 2011;306(23):2610-1. [pmid: 22187282].
31 Tosetti F, Ferrari N, De Flora S, et al. Angioprevention: angiogenesis is a common and key target for cancer chemopreventive agents. FASEB J. 2002;16(1):2-14. [pmid: 11772931].
32 Ashino H, Shimamura M, Nakajima H, et al. Novel function of ascorbic acid as an angiostatic factor. Angiogenesis. 2003;6(4):259-69. [pmid: 15166494].
33 Reifen R. Vitamin A as an anti-inflammatory agent. Proc Nutr Soc. 2002;61(3):397-400. [pmid: 12230799].
34 Bogden JD. Influence of zinc on immunity in the elderly. J Nutr Health Aging. 2004;8(1):48-54. [pmid: 14730367].
35 Villamor E, Fawzi WW. Effects of vitamin A supplementation on immune responses and correlation with clinical outcomes. Clin Microbiol Rev. 2005;18(3):446-64. [pmid: 16020684].
36 Huang HY, Berndt S, Helzlsouer KJ. Vitamin E as a cancer chemopreventive agent. Kelloff GJ, Hawk ET, Sigman CC, editors. Cancer Chemoprevention. Volume 1: Promising Cancer Chemopreventive Agents. New Jersey. Humana Press. 2004.
37 Morris CD, Carson S. Routine Vitamin Supplementation to Prevent Cardiovascular Disease: A Summary of the Evidence for the U.S. Preventive Services Task Force. AHRQ Publication No. 03-523B. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
38 Ritenbaugh C, Streit K, Helfand M. Routine Vitamin Supplementation to Prevent Cancer: A Summary of Evidence From Randomized, Controlled Trials for the U.S. Preventive Services Task Force. AHRQ Publication No. 03-523C. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
39 Atkins D, Shetty P. Routine Vitamin Supplementation to Prevent Cancer: Update of the Evidence From Randomized, Controlled Trials, 1999-2002. AHRQ Publication No. 03-523D. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
40 Huang HY, Caballero B, Chang S, et al. Multivitamin/Mineral Supplements and Prevention of Chronic Disease. AHRQ Publication No. 139. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
41 Gordis L. Epidemiology. Philadelphia. Saunders Elsevier. 2009.
42 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
43 Human Development Report 2011. Sustainability and Equity: A Better Future for All. New York. United Nations Development Programme. 2011.
44 U.S. Preventive Services Task Force. Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
45 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
46 Bradburn MJ, Deeks JJ, Altman DG. Metan-a command for meta-analysis in Stata. Sterne JA, editor. Meta-Analysis in Stata: An Updated Collection From the Stata Journal. College Station, TX. Stata Press. 1998:3-28.
47 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1187-97. [pmid: 21477993].
48 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
49 Hercberg S, Galan P, Preziosi P, et al. The SU.VI.MAX study: a randomized, placebo-controlled trial of the health effects of antioxidant vitamins and minerals. Arch Intern Med. 2004;164(21):2335-42. [pmid: 15557412].
50 Gaziano J, Sesso HD, Christen HJ, et al. Multivitamins in the prevention of cancer in men: the Physicians' Health Study II randomized controlled trial. JAMA. 2012;308(18):1871-80. [pmid: 23162860].
51 Chylack LT Jr, Brown NP, Bron A, et al. The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 2002;9(1):49-80. [pmid: 11815895].
52 Graat JM, Schouten EG, Kok FJ. Effect of daily vitamin E and multivitamin-mineral supplementation on acute respiratory tract infections in elderly persons: a randomized controlled trial. JAMA. 2002;288(6):715-21. [pmid: 12169075].
53 Feskanich D, Singh V, Willett WC, et al. Vitamin A intake and hip fractures among postmenopausal women. JAMA. 2002;287(1):47-54. [pmid: 11754708].
54 Hercberg S, Galan P, Preziosi P, et al. Background and rationale behind the SU.VI.MAX study, a prevention trial using nutritional doses of a combination of antioxidant vitamins and minerals to reduce cardiovascular diseases and cancers. Int J Vitam Nutr Res. 1998;68(1):3-20. [pmid: 9503043].
55 Meyer F, Galan P, Douville P, et al. Antioxidant vitamin and mineral supplementation and prostate cancer prevention in the SU.VI.MAX trial. Int J Cancer. 2005;116(2):182-6. [pmid: 15800922].
56 Hercberg S, Kesse-Guyot E, Druesne-Pecollo N, et al. Incidence of cancers, ischemic cardiovascular diseases and mortality during 5-year follow-up after stopping antioxidant vitamins and minerals supplements: a postintervention follow-up in the SU.VI.MAX study. Int J Cancer. 2010;127(8):1875-81. [pmid: 20104528].
57 Sesso HD, Christen WG, Bubes V, et al. Multivitamins in the prevention of cardiovascular disease in men: the Physicians' Health Study II randomized controlled trial. JAMA. 2012;308(17):1751-60. [pmid: 23117775].
58 Hercberg S, Ezzedine K, Guinot C, et al. Antioxidant supplementation increases the risk of skin cancers in women but not in men. J Nutr. 2007;137(9):2098-105. [pmid: 17709449].
59 Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330(15):1029-35. [pmid: 8127329].
60 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;334(18):1150-5. [pmid: 8602180].
61 Hennekens CH, Buring JE, Manson JE, et al. Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334(18):1145-9. [pmid: 8602179].
62 Lee IM, Cook NR, Manson JE, et al. Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women's Health Study. J Natl Cancer Inst. 1999;91(24):2102-6. [pmid: 10601381].
63 Greenberg ER, Baron JA, Stukel TA, et al., Skin Cancer Prevention Study Group. A clinical trial of beta carotene to prevent basal-cell and squamous-cell cancers of the skin. N Engl J Med. 1990;323(12):789-95. [pmid: 2202901].
64 Green A, Williams G, Neale R, et al. Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet. 1999;354(9180):723-9. [pmid: 10475183].
65 Liu S, Ajani U, Chae C, et al. Long-term beta-carotene supplementation and risk of type 2 diabetes mellitus: a randomized controlled trial. JAMA. 1999;282(11):1073-5. [pmid: 10493207].
66 Kataja-Tuomola M, Sundell JR, Mannisto S, et al. Effect of alpha-tocopherol and beta-carotene supplementation on the incidence of type 2 diabetes. Diabetologia. 2008;51(1):47-53. [pmid: 17994292].
67 Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the Beta-Carotene and Retinol Efficacy Trial. J Natl Cancer Inst. 1996;88(21):1550-9. [pmid: 8901853].
68 Cook NR, Le IM, Manson JE, et al. Effects of beta-carotene supplementation on cancer incidence by baseline characteristics in the Physicians' Health Study (United States). Cancer Causes Control. 2000;11(7):617-26. [pmid: 10977106].
69 Rautalahti MT, Virtamo JR, Taylor PR, et al. The effects of supplementation with alpha-tocopherol and beta-carotene on the incidence and mortality of carcinoma of the pancreas in a randomized, controlled trial. Cancer. 1999;86(1):37-42. [pmid: 10391561].
70 Malila N, Taylor PR, Virtanen MJ, et al. Effects of alpha-tocopherol and beta-carotene supplementation on gastric cancer incidence in male smokers (ATBC Study, Finland). Cancer Causes Control. 2002;13(7):617-23. [pmid: 12296509].
71 Virtamo J, Edwards BK, Virtanen M, et al. Effects of supplemental alpha-tocopherol and beta-carotene on urinary tract cancer: incidence and mortality in a controlled trial (Finland). Cancer Causes Control. 2000;11(10):933-9. [pmid: 11142528].
72 Wright ME, Virtamo J, Hartman AM, et al. Effects of alpha-tocopherol and beta-carotene supplementation on upper aerodigestive tract cancers in a large, randomized controlled trial. Cancer. 2007;109(5):891-8. [pmid: 17265529].
73 Virtamo J, Pietinen P, Huttunen JK, et al. Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. 2003;290(4):476-85. [pmid: 12876090].
74 Goodman GE, Thornquist MD, Balmes J, et al. The Beta-Carotene and Retinol Efficacy Trial: incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping beta-carotene and retinol supplements. J Natl Cancer Inst. 2004;96(23):1743-50. [pmid: 15572756].
75 Greenberg ER, Baron JA, Karagas MR, et al. Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. 1996;275(9):699-703. [pmid: 8594267].
76 Heinonen OP, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90(6):440-6. [pmid: 9521168].
77 Albanes D, Malila N, Taylor PR, et al. Effects of supplemental alpha-tocopherol and beta-carotene on colorectal cancer: results from a controlled trial (Finland). Cancer Causes Control. 2000;11(3):197-205. [pmid: 10782653].
78 Hemila H, Virtamo J, Albanes D, et al. Vitamin E and beta-carotene supplementation and hospital-treated pneumonia incidence in male smokers. Chest. 2004;125(2):557-65. [pmid: 14769738].
79 Salonen JT, Nyyssonen K, Salonen R, et al. Antioxidant Supplementation in Atherosclerosis Prevention (ASAP) study: a randomized trial of the effect of vitamins E and C on 3-year progression of carotid atherosclerosis. J Intern Med. 2000;248(5):377-86. [pmid: 11123502].
80 Sesso HD, Buring JE, Christen WG, et al. Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians' Health Study II randomized controlled trial. JAMA. 2008;300(18):2123-33. [pmid: 18997197].
81 Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women's Health Study: a randomized controlled trial. JAMA. 2005;294(1):56-65. [pmid: 15998891].
82 Lippman SM, Klein EA, Goodman PJ, et al. Effect of selenium and vitamin E on risk of prostate cancer and other cancers: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. 2009;301(1):39-51. [pmid: 19066370].
83 Gaziano JM, Glynn RJ, Christen WG, et al. Vitamins E and C in the prevention of prostate and total cancer in men: the Physicians' Health Study II randomized controlled trial. JAMA. 2009;301(1):52-62. [pmid: 19066368].
84 Ridker PM, Cook NR, Lee IM, et al. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women: editorial comment. Obstet Gynecol Surv. 2005;60(8):519-21. [pmid: 15753114].
85 Steering Committee of the Physicians' Health Study Research Group. Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1989;321(3):129-35. [pmid: 2664509].
86 Lotan Y, Goodman P, Youssef R, et al. Evaluation of vitamin E and selenium supplementation on the prevention of bladder cancer in SWOG coordinated select. J Urol. 2012;187(6):2005-10. [pmid: 22498220].
87 Hemila H, Kaprio J. Vitamin E supplementation and pneumonia risk in males who initiated smoking at an early age: effect modification by body weight and dietary vitamin C. Nutr J. 2008;7:33. [pmid: 19019244].
88 Hemila H, Kaprio J. Subgroup analysis of large trials can guide further research: a case study of vitamin E and pneumonia. Clin Epidemiol. 2011;3(1):51-9. [pmid: 21386974].
89 Clark LC, Combs GF Jr, Turnbull BW, et al., Nutritional Prevention of Cancer Study Group. Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. JAMA. 1996;276(24):1957-63. [pmid: 8971064].
90 Duffield-Lillico AJ, Reid ME, Turnbull BW, et al. Baseline characteristics and the effect of selenium supplementation on cancer incidence in a randomized clinical trial: a summary report of the Nutritional Prevention of Cancer Trial. Cancer Epidemiol Biomarkers Prev. 2002;11(7):630-9. [pmid: 12101110].
91 Rayman MP, Blundell-Pound G, Pastor-Barriuso R, et al. A randomized trial of selenium supplementation and risk of type-2 diabetes, as assessed by plasma adiponectin. PLoS One. 2012;7(9):e45269. [pmid: 23028897].
92 Combs GF Jr, Clark LC, Turnbull BW. Reduction of cancer mortality and incidence by selenium supplementation. Med Klin (Munich). 1997;92(Suppl 3):42-5. [pmid: 9342915].
93 Clark LC, Dalkin B, Krongrad A, et al. Decreased incidence of prostate cancer with selenium supplementation: results of a double-blind cancer prevention trial. Br J Urol. 1998;81(5):730-4. [pmid: 9634050].
94 Reid ME, Duffield-Lillico AJ, Garland L, et al. Selenium supplementation and lung cancer incidence: an update of the nutritional prevention of cancer trial. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1285-91. [pmid: 12433704].
95 Duffield-Lillico AJ, Dalkin BL, Reid ME, et al. Selenium supplementation, baseline plasma selenium status and incidence of prostate cancer: an analysis of the complete treatment period of the Nutritional Prevention of Cancer Trial. BJU Int. 2003;91(7):608-12. [pmid: 12699469].
96 Lim LS, Harnack LJ, Lazovich D, et al. Vitamin A intake and the risk of hip fracture in postmenopausal women: the Iowa Women's Health Study. Osteoporos Int. 2004;15(7):552-9. [pmid: 14760518].
97 Moon TE, Levine N, Cartmel B, et al., Southwest Skin Cancer Prevention Study Group. Effect of retinol in preventing squamous cell skin cancer in moderate-risk subjects: a randomized, double-blind, controlled trial. Cancer Epidemiol Biomarkers Prev. 1997;6(11):949-56. [pmid: 9367069].
98 Levine N, Moon TE, Cartmel B, et al., Southwest Skin Cancer Prevention Study Group. Trial of retinol and isotretinoin in skin cancer prevention: a randomized, double-blind, controlled trial. Cancer Epidemiol Biomarkers Prev. 1997;6(11):957-61. [pmid: 9367070].
99 Melhus H, Michaelsson K, Kindmark A, et al. Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture. Ann Intern Med. 1998;129(10):770-8. [pmid: 9841582].
100 Promislow JH, Goodman-Gruen D, Slymen DJ, et al. Retinol intake and bone mineral density in the elderly: the Rancho Bernardo Study. J Bone Miner Res. 2002;17(8):1349-58. [pmid: 12162487].
101 Cole BF, Baron JA, Sandler RS, et al. Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. 2007;297(21):2351-9. [pmid: 17551129].
102 Figueiredo JC, Grau MV, Haile RW, et al. Folic acid and risk of prostate cancer: results from a randomized clinical trial. J Natl Cancer Inst. 2009;101(6):432-5. [pmid: 19276452].
103 Avenell A, MacLennan GS, Jenkinson DJ, et al. Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). J Clin Endocrinol Metab. 2012;97(2):614-22. [pmid: 22112804].
104 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 2003;326(7387):469. [pmid: 12609940].
105 Dean AJ, Bellgrove MA, Hall T, et al. Effects of vitamin D supplementation on cognitive and emotional functioning in young adults—a randomised controlled trial. PLoS One. 2011;6(11):e25966. [pmid: 22073146].
106 Ford JA, MacLennan G, Bolland MJ, et al. Vitamin D supplementation prevents cardiac failure; MRC record trial analysis, systematic review and meta-analysis. Circulation. 2012;126:A18397.
107 Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium or Vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365(9471):1621-8. [pmid: 15885294].
108 Wactawski-Wende J, Kotchen JM, Anderson GL, et al. Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684-96. [pmid: 16481636].
109 Lappe JM, Travers-Gustafson D, Davies KM, et al. Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 2007;85(6):1586-91. [pmid: 17556697].
110 de Boer I, Tinker LF, Connelly S, et al. Calcium plus vitamin D supplementation and the risk of incident diabetes in the Women's Health Initiative. Diabetes Care. 2008;31(4):701-7. [pmid: 18235052].
111 Bolland MJ, Grey A, Gamble GD, et al. Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women's Health Initiative (WHI) limited-access data set. Am J Clin Nutr. 2011;94(4):1144-9. [pmid: 21880848].
112 Prentice RL, Pettinger MB, Jackson RD, et al. Health risks and benefits from calcium and vitamin D supplementation: Women's Health Initiative clinical trial and cohort study. Osteoporos Int. 2013;24(2):567-80. [pmid: 23208074].
113 Bolland MJ, Barber PA, Doughty RN, et al. Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 2008;336(7638):262-6. [pmid: 18198394].
114 Baron JA, Beach M, Wallace K, et al. Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 2005;14(3):586-9. [pmid: 15767334].
115 Reid IR, Mason B, Horne A, et al. Randomized controlled trial of calcium in healthy older women. Am J Med. 2006;119(9):777-85. [pmid: 16945613].
116 Baron JA, Beach M, Mandel JS, et al., Calcium Polyp Prevention Study Group. Calcium supplements for the prevention of colorectal adenomas. N Engl J Med. 1999;340(2):101-7. [pmid: 9887161].
117 Jeon YJ, Myung SK, Lee EH, et al. Effects of beta-carotene supplements on cancer prevention: meta-analysis of randomized controlled trials. Nutr Cancer. 2011;63(8):1196-207. [pmid: 21981610].
118 Fritz H, Kennedy D, Fergusson D, et al. Selenium and lung cancer: a systematic review and meta analysis. PLoS One. 2011;6(11):e26259. [pmid: 22073154].
119 Flores-Mateo G, Navas-Acien A, Pastor-Barriuso R, et al. Selenium and coronary heart disease: a meta-analysis. Am J Clin Nutr. 2006;84(4):762-73. [pmid: 17023702].
120 Wang L, Manson JE, Song Y, et al. Systematic review: vitamin D and calcium supplementation in prevention of cardiovascular events. Ann Intern Med. 2010;152(5):315-23. [pmid: 20194238].
121 Autier P, Gandini S. Vitamin D supplementation and total mortality: a meta-analysis of randomized controlled trials. Arch Intern Med. 2007;167(16):1730-7. [pmid: 17846391].
122 Bjelakovic G, Nikolova D, Simonetti RG, et al. Systematic review: primary and secondary prevention of gastrointestinal cancers with antioxidant supplements. Aliment Pharmacol Ther. 2008;28(6):689-703. [pmid: 19145725].
123 Bjelakovic G, Nikolova D, Simonetti RG, et al. Antioxidant supplements for preventing gastrointestinal cancers. Cochrane Database Syst Rev. 2008;(3):CD004183. [pmid: 18677777].
124 Bjelakovic G, Nikolova D, Gluud LL, et al. Antioxidant supplements for prevention of mortality in healthy participants and patients with various diseases. Cochrane Database Syst Rev. 2008;(2):CD007176. [pmid: 18425980].
125 Papaioannou D, Cooper KL, Carroll C, et al. Antioxidants in the chemoprevention of colorectal cancer and colorectal adenomas in the general population: a systematic review and meta-analysis. Colorectal Dis. 2011;13(10):1085-99. [pmid: 20412095].
126 Chang YJ, Myung SK, Chung ST, et al. Effects of vitamin treatment or supplements with purported antioxidant properties on skin cancer prevention: a meta-analysis of randomized controlled trials. Dermatology. 2011;223(1):36-44. [pmid: 21846961].
127 Rees K, Hartley L, Day C, et al. Selenium supplementation for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2013;(1):CD009671. [pmid: 23440843].
128 Abner EL, Schmitt FA, Mendiondo MS, et al. Vitamin E and all-cause mortality: a meta-analysis. Curr Aging Sci. 2011;4(2):158-70. [pmid: 21235492].
129 Alkhenizan A, Hafez K. The role of vitamin E in the prevention of cancer: a meta-analysis of randomized controlled trials. Ann Saudi Med. 2007;27(6):409-14. [pmid: 18059122].
130 Shekelle P, Coulter I, Hardy M, et al. Effect of the Supplemental Use of Antioxidants Vitamin C, Vitamin E, and Coenzyme Q10 for the Prevention and Treatment of Cancer. AHRQ Publication No. 04-E003. Rockville, MD. Agency for Healthcare Research and Quality. 2003.
131 Shekelle PG, Morton SC, Jungvig LK, et al. Effect of supplemental vitamin E for the prevention and treatment of cardiovascular disease. J Gen Intern Med. 2004;19(4):380-9. [pmid: 15061748].
132 Bin Q, Hu X, Cao Y, et al. The role of vitamin E (tocopherol) supplementation in the prevention of stroke. A meta-analysis of 13 randomised controlled trials. Thromb Haemost. 2011;105(4):579-85. [pmid: 21264448].
133 Mursu J, Robien K, Harnack LJ, et al. Dietary supplements and mortality rate in older women: the Iowa Women's Health Study. Arch Intern Med. 2011;171(18):1625-33. [pmid: 21987192].
134 Tanvetyanon T, Bepler G. Beta-carotene in multivitamins and the possible risk of lung cancer among smokers versus former smokers: a meta-analysis and evaluation of national brands. Cancer. 2008;113(1):150-7. [pmid: 18429004].
135 Cortes-Jofre M, Rueda JR, Corsini-Munoz G, et al. Drugs for preventing lung cancer in healthy people. Cochrane Database Syst Rev. 2012;(10):CD002141. [pmid: 23076895].
136 Bolland MJ, Avenell A, Baron JA, et al. Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ. 2010;341:c3691. [pmid: 20671013].
137 Bolland MJ, Grey A, Avenell A, et al. Calcium supplements with or without vitamin D and risk of cardiovascular events: reanalysis of the Women's Health Initiative limited access dataset and meta-analysis. BMJ. 2011;342:d2040. [pmid: 21505219].
138 Prince RL, Devine A, Dhaliwal SS, et al. Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med. 2006;166(8):869-75. [pmid: 16636212].
139 Xiao Q, Murphy RA, Houston DK, et al. Dietary and supplemental calcium intake and cardiovascular disease mortality: the National Institutes of Health-AARP Diet and Health Study. JAMA Intern Med. 2013;173(8):639-46. [pmid: 23381719].
140 Li K, Kaaks R, Linseisen J, et al. Associations of dietary calcium intake and calcium supplementation with myocardial infarction and stroke risk and overall cardiovascular mortality in the Heidelberg cohort of the European Prospective Investigation into Cancer and Nutrition study (EPIC-Heidelberg). Heart. 2012;98(12):920-5. [pmid: 22626900].
141 Byers T. Anticancer vitamins du Jour—the ABCED's so far. Am J Epidemiol. 2010;172(1):1-3. [pmid: 20562190].
142 Lichtenstein AH, Russell RM. Essential nutrients: food or supplements? Where should the emphasis be?. JAMA. 2005;294(3):351-8. [pmid: 16030280].
143 Klein EA, Thompson IM Jr, Tangen CM, et al. Vitamin E and the risk of prostate cancer: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. 2011;306(14):1549-56. [pmid: 21990298].
144 Blot WJ, Li JY, Taylor PR, et al. Nutrition intervention trials in Linxian, China: supplementation with specific vitamin/mineral combinations, cancer incidence, and disease-specific mortality in the general population. J Natl Cancer Inst. 1993;85(18):1483-92. [pmid: 8360931].
145 Lappe JM, Heaney RP. Why randomized controlled trials of calcium and vitamin D sometimes fail. Dermatoendocrinol. 2012;4(2):95-100. [pmid: 22928064].
146 U.S. Preventive Services Task Force. Vitamin D and calcium supplementation to prevent fractures in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;158(9):1-36. [pmid: 23277895].
147 Marra MV, Boyar AP. Position of the American Dietetic Association: nutrient supplementation. J Am Diet Assoc. 2009;109(12):2073-85. [pmid: 19957415].
148 American Heart Association. Vitamin and Mineral Supplements. Dallas. American Heart Association. 2013. Accessed at http://www.heart.org/HEARTORG/GettingHealthy/NutritionCenter/Vitamin-and-Mineral-Supplements_UCM_306033_Article.jsp on 7 October 2013.
149 American Institute for Cancer Research. Food, Nutrition, Physical Activity, and the Prevention of Cancer: A Global Perspective. Washington, DC. American Institute for Cancer Research. 2007.
150 National Institutes of Health State-of-the-Science Panel. National Institutes of Health State-of-the-Science Conference Statement: multivitamin/mineral supplements and chronic disease prevention. Am J Clin Nutr. 2007;85(1):257S-64S. [pmid: 17209206].
151 Ezzedine K, Latreille J, Kesse-Guyot E, et al. Incidence of skin cancers during 5-year follow-up after stopping antioxidant vitamins and mineral supplementation. Eur J Cancer. 2010;46(18):3316-22. [pmid: 20605091].
152 Hercberg S, Czernichow S, Galan P. Antioxidant vitamins and minerals in prevention of cancers: lessons from the SU.VI.MAX study. Br J Nutr. 2006;96(Suppl 1):S28-30. [pmid: 16923246].
153 Hercberg S, Preziosi P, Briancon S, et al. A primary prevention trial using nutritional doses of antioxidant vitamins and minerals in cardiovascular diseases and cancers in a general population: the SU.VI.MAX study—design, methods, and participant characteristics. Control Clin Trials. 1998;19(4):336-51. [pmid: 9683310].
154 Christen WG, Gaziano JM, Hennekens CH. Design of Physicians' Health Study II—a randomized trial of beta-carotene, vitamins E and C, and multivitamins, in prevention of cancer, cardiovascular disease, and eye disease, and review of results of completed trials. Ann Epidemiol. 2000;10(2):125-34. [pmid: 10691066].
155 Albanes D, Heinonen OP, Huttunen JK, et al. Effects of alpha-tocopherol and beta-carotene supplements on cancer incidence in the Alpha-Tocopherol Beta-Carotene Cancer Prevention Study. Am J Clin Nutr. 1995;62(6 Suppl):1427S-30S. [pmid: 7495243].
156 Albanes D, Heinonen OP, Taylor PR, et al. Alpha-tocopherol and beta-carotene supplements and lung cancer incidence in the Alpha-Tocopherol Beta-Carotene Cancer Prevention Study: effects of base-line characteristics and study compliance. J Natl Cancer Inst. 1996;88(21):1560-70. [pmid: 8901854].
157 Heinonen OP, Huttenen JK, Albanes D. The Alpha-Tocopherol, Beta-Carotene Lung Cancer Prevention Study: design, methods, participant characteristics, and compliance. Ann Epidemiol. 1994;4(1):1-10. [pmid: 8205268].
158 The Steering Committee of the Physicians'Health Study Research Group. Preliminary report: findings from the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1988;318(4):262-4. [pmid: 3275899].
159 Greenberg ER, Baron JA, Stevens MM, et al. The Skin Cancer Prevention Study: design of a clinical trial of beta-carotene among persons at high risk for nonmelanoma skin cancer. Control Clin Trials. 1989;10(2):153-66. [pmid: 2666024].
160 Green A, Battistutta D, Hart V, et al. The Nambour Skin Cancer and Actinic Eye Disease Prevention Trial: design and baseline characteristics of participants. Control Clin Trials. 1994;15(6):512-22. [pmid: 7851112].
161 Goodman GE, Omenn GS, Thornquist MD, et al. The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with cigarette smokers. Cancer Epidemiol Biomarkers Prev. 1993;2(4):389-96. [pmid: 8348063].
162 Neuhouser ML, Barnett MJ, Kristal AR, et al. Dietary supplement use and prostate cancer risk in the Carotene and Retinol Efficacy Trial. Cancer Epidemiol Biomarkers Prev. 2009;18(8):2202-6. [pmid: 19661078].
163 Omenn GS, Goodman GE, Thornquist MD, et al. The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with asbestos-exposed workers. Cancer Epidemiol Biomarkers Prev. 1993;2(4):381-7. [pmid: 8348062].
164 Omenn GS, Goodman G, Thornquist M, et al. The Carotene and Retinol Efficacy Trial (CARET) for chemoprevention of lung cancer in high risk populations: smokers and asbestos-exposed workers. Cancer Res. 1994;54(7 Suppl):2038s-43s. [pmid: 8137335].
165 Chae CU, Albert CM, Moorthy MV, et al. Vitamin E supplementation and the risk of heart failure in women. Circ Heart Fail. 2012;5(2):176-82. [pmid: 22438520].
166 Dunn BK, Ryan A, Ford LG. Selenium and Vitamin E Cancer Prevention Trial: a nutrient approach to prostate cancer prevention. Recent Results Cancer Res. 2009;181:183-93. [pmid: 19213568].
167 Dunn BK, Richmond ES, Minasian LM, et al. A nutrient approach to prostate cancer prevention: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). Nutr Cancer. 2010;62(7):896-918. [pmid: 20924966].
168 Klein EA, Thompson IM, Lippman SM, et al. SELECT: the Selenium and Vitamin E Cancer Prevention Trial: rationale and design. Prostate Cancer Prostatic Dis. 2000;3(3):145-51. [pmid: 12497090].
169 Lippman SM, Goodman PJ, Klein EA, et al. Designing the Selenium and Vitamin E Cancer Prevention Trial (SELECT). J Natl Cancer Inst. 2005;97(2):94-102. [pmid: 15657339].
170 Walsh PC. Re: Vitamin E and the risk of prostate cancer: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). J Urol. 2012;187(5):1640-1. [pmid: 22494720].
171 Wyatt G. Vitamin E increases prostate cancer risk in middle-aged men relative to placebo: no significant association observed with selenium, either alone or in combination with vitamin E. Evid Based Nurs. 2012;15(3):90-1. [pmid: 22411161].
172 Reid ME, Duffield-Lillico AJ, Slate E, et al. The nutritional prevention of cancer: 400 mcg per day selenium treatment. Nutr Cancer. 2008;60(2):155-63. [pmid: 18444146].
173 Stranges S, Marshall JR, Trevisan M, et al. Effects of selenium supplementation on cardiovascular disease incidence and mortality: secondary analyses in a randomized clinical trial. Am J Epidemiol. 2006;163(8):694-9. [pmid: 16495471].
174 Moon TE, Levine N, Cartmel B, et al., Southwest Skin Cancer Prevention Study Group. Design and recruitment for retinoid Skin Cancer Prevention (SKICAP) trials. Cancer Epidemiol Biomarkers Prev. 1995;4(6):661-9. [pmid: 8547834].
175 Lappe JM, Davies KM, Travers-Gustafson D, et al. Vitamin D status in a rural postmenopausal female population. J Am Coll Nutr. 2006;(5):395-402. [pmid: 17031008].
176 Bolland MJ, Grey A, Gamble GD, et al. Risk of cardiovascular events with calcium/vitamin D: a reanalysis of the Women's Health Initiative. J Bone Miner Res. 2010;25:S50.
177 Brunner RL, Wactawski-Wende J, Caan BJ, et al. The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women's Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutr Cancer. 2011;63(6):827-41. [pmid: 21774589].
178 Chlebowski RT, Johnson KC, Kooperberg C, et al. Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. 2008;100(22):1581-91. [pmid: 19001601].
179 Ding EL, Mehta S, Fawzi WW, et al. Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women's Health Initiative randomized trial. Int J Cancer. 2008;122(8):1690-4. [pmid: 18092326].
180 Hays J, Hunt JR, Hubbell FA, et al. The Women's Health Initiative recruitment methods and results. Ann Epidemiol. 2003;13(9 Suppl):S18-S77. [pmid: 14575939].
181 Hsia J, Heiss G, Ren H, et al. Calcium/vitamin D supplementation and cardiovascular events. Circulation. 2007;115(7):846-54. [pmid: 17309935].
182 Jackson RD, LaCroix AZ, Gass M, et al. Calcium plus vitamin D supplementation and the risk of fractures. New Engl J Med. 2006;354(7):669-83. [pmid: 16481635].
183 LaCroix AZ, Kotchen J, Anderson G, et al. Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women's Health Initiative calcium-vitamin D randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2009;64(5):559-67. [pmid: 19221190].
184 Tang JY, Fu T, Leblanc E, et al. Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer: post hoc analyses of the Women's Health Initiative randomized controlled trial. J Clin Oncol. 2011;29(22):3078-84. [pmid: 21709199].
185 Fu T, Tang JY, Leblanc E, et al. Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer. J Invest Dermatol. 2011;131(Suppl 1):S35.
186 Reid IR, Horne A, Mason B, et al. Effects of calcium supplementation on body weight and blood pressure in normal older women: a randomized controlled trial. J Clin Endocrinol Metab. 2005;90(7):3824-9. [pmid: 15827103].
187 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
188 Adjei AA. Calcitriol in Preventing Lung Cancer in Smokers and Former Smokers at High Risk of Lung Cancer. Buffalo, NY. Roswell Park Cancer Institute. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT00690924 on 7 October 2013.
189 Camargo CA Jr. Effect of Vitamin D Supplementation on Cardiovascular and Respiratory Disease Event Rates, and the Incidence of Fractures. New Zealand. University of Auckland. 2011. Accessed at http://www.anzctr.org.au/trial_view.aspx?id=336777 on 7 October 2013.
190 Goossens ME, Buntinx F, Joniau S, et al. Designing the Selenium and Bladder Cancer Trial (SELEBLAT), a phase lll randomized chemoprevention study with selenium on recurrence of bladder cancer in Belgium. BMC Urology. 2012;12:8. [pmid: 22436453].
191 Lance MP. Effect of Vitamin E and/or Selenium on Colorectal Polyps in Men Enrolled in SELECT Trial SWOG-S0000. Tucson, AZ. University of Arizona. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00706121 on 7 October 2013.
192 Lappe J. Clinical Trial of Vitamin D3 to Reduce Cancer Risk in Postmenopausal Women (CAPS). Fremont, Nebraska. Creighton University. 2012. Accessed at http://clinicaltrials.gov/show/NCT01052051 on 7 October 2013.
193 Lopez-Torres Hidalgo J, ANVITAD Group. Prevention of falls and fractures in old people by administration of calcium and vitamin D, randomized clinical trial. BMC Public Health. 2011;11:910. [pmid: 22151975].
194 Manson JE, Bassuk SS, Lee IM, et al. The Vitamin D and Omega-3 Trial (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012;33(1):159-71. [pmid: 21986389].
195 Peto J. Vitamin D and Longevity (VIDAL) Trial: Randomized Feasibility Study. London. London School of Hygiene and Tropical Medicine. 2012. Accessed at http://www.controlled-trials.com/ISRCTN46328341 on 7 October 2013.
196 Rhodes LE. The Effect of Green Tea and Vitamin C on Skin Health. Manchester. University of Manchester. 2009. Accessed at http://clinicaltrials.gov/ct2/show/NCT01032031 on 7 October 2013.
197 Tran B, Armstrong BK, Carlin JB, et al. Recruitment and results of a pilot trial of vitamin D supplementation in the general population of Australia. J Clin Endocrinol Metab. 2012;97(12):4473-80. [pmid: 23066119].
198 Tuomainen T, Virtanen J, Voutilainen S. Finnish Vitamin D Trial (FIND). Joensuu, Finland. University of Eastern Finland. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01463813 on 7 October 2013.