# Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in updating its 2003 recommendation on using vitamin supplements to prevent CVD and cancer.1 Our review included 26 studies (24 RCTs and two cohort studies) examining the benefits and harms of vitamins and minerals as primary prevention of CVD, cancer, and all-cause mortality (Table 44). For most of the supplements analyzed in this report, we found no evidence of an effect for nutritional doses on CVD, cancer, or all-cause mortality in healthy individuals with a presumed generally adequate diet based on study inclusion criteria and baseline serum levels. Other systematic reviews generally support this perspective.117-127 For most supplements, however, there were a limited number of studies on which to base this conclusion, with the exception of vitamin E, which included six fair- to good-quality trials that all produced clearly null effects on these endpoints, consistent with the conclusions of other systematic reviews and meta-analyses.128-132

Table 44 Summary of Evidence of Included Studies

KQ | Supplement | # of studies (k), N randomized (n)^†^ | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of findings
KQ 1 (efficacy) | MVI | k=3, n=27,955 | RCT | Only 2 studies examining the efficacy of MVI on cancer and CVD; 49,50 generalizability may be an issue as protective effect seen only in men among healthy subjects; only 1 study included women | Consistent | Moderate-to-high: healthy adult volunteers in France; healthy U.S. male physicians; primary care adult patients in the United States and United Kingdom with cataracts | Good | 2 RCTs examining efficacy of MVI on cancer and CVD incidence and mortality,49,50 minor protective effect against cancer in men but not women; similar pattern for all-cause mortality. Small number of deaths reported in third RCT and likely unreliable.51
KQ 2 (harms) | MVI | k=5, n=100,944 | RCT (k=4), prospective cohort study (k=1) | | Consistent | Moderate-to-high: healthy adult volunteers from France, male physicians and female nurses from the United States; primary care adult patients in the United States and United Kingdom with cataracts; Dutch elderly patients | Good | Increased risk of hip fractures among MVI users compared with nonusers in 1 study (may be due to vitamin A).53 4 RCTs reported no difference between groups in the number of hypercarotenemia cases, other side effects, and intercurrent illnesses and respiratory tract infections.49-52 Mixed results for bleeding.50
KQ 3 (efficacy) | Beta-carotene | k=6, n=112,820 | RCT | 1 trial discontinued early due to increased risk of lung cancer and related deaths;60 another discontinued due to reported harms from other trials62 | Consistent | Moderate-to-high: increased risk for lung cancer (smokers and/or asbestos-exposed workers), healthy male physicians or female nurses from the United States; participants with a previous history of BCC and/or SCC | Good | Increased risk of lung cancer incidence and mortality and all-cause mortality among participants at high-risk for lung cancer at baseline (i.e., smokers and/or asbestos-exposed workers).59,60
KQ 3 (efficacy) | Vitamin E | k=5, n=120,335 | RCT | | Consistent | Moderate-to-high: healthy men (general population or physicians) and female nurses; individuals with hypercholesterolemia; male smokers in the United States | Good | No effect on CVD, cancer, or all-cause mortality.
KQ 3 (efficacy) | Selenium | k=2, n=36,845 | RCT | 1 trial discontinued early due to no treatment effect; other study used secondary analyses of CVD and cancer outcomes | Inconsistent | Moderate-to-high: healthy men and men with a previous SCC or BCC from the United States | Good | No effect on CVD or all-cause mortality; however, mixed results for effects on any cancer and site-specific cancers, with 1 small trial finding statistically significant reduced risks89 and the other finding NSD between selenium alone or when combined with vitamin E.82
KQ 3 (efficacy) | Vitamin A | k=2, n=20,611 | RCT | Subjects taken out of study during years 4 and 5 due to funding issues in 1 trial; the other trial discontinued early due to increased risk of lung cancer and related deaths associated with beta-carotene supplementation | Consistent | Moderate: participants with a history of actinic keratosis; heavy smokers or asbestos-exposed workers in the United States | Good | Vitamin A appears to have no effect on CVD, cancer, or mortality. Increased risk of lung cancer incidence and mortality and all-cause mortality among participants at high risk for lung cancer at baseline (i.e., smokers and/or asbestos-exposed workers) attributed to beta-carotene component of vitamin A and beta-carotene combination supplement.60
KQ 3 (efficacy) | Vitamin C | k=2, n=15,161 | RCT | 1 study did not report results using its 2×2 factorial design, which may have limited power79 | Consistent | Moderate: healthy U.S. male physicians and subjects with hypercholesterolemia in Denmark | Fair | No effect on CVD, cancer, or mortality.79,80
KQ 3 (efficacy) | Folic acid | k=1, n=1,021 | RCT | Secondary analysis of CVD and cancer in a study examining colorectal adenomas | NA | Low: recruited participants with a recent history of colorectal adenomas | Fair | Secondary analysis showed more noncolorectal cancer incident cases in folic acid group than placebo (p=0.02), attributed to higher number of prostate cancers in intervention group. NSD between groups on CVD outcomes.101
KQ 3 (efficacy) | Vitamin D | k=2, n=7,978 | RCT | Includes a 2×2 factorial study of vitamin D and calcium | Consistent | High: Older adults from United States and United Kingdom | Fair | No effect on CVD, cancer, or mortality.
KQ 3 (efficacy) | Calcium | k=4, n=8,873 | RCT | Includes a 2×2 factorial study of vitamin D and calcium | Consistent | Moderate: older women from United States, United Kingdom, and New Zealand; results may not be applicable to men or younger age groups | Fair | No effect on CVD, cancer, or mortality; when pooled, 2 trials showed a negative effect on colorectal cancer incidence.103,109
KQ 3 (efficacy) | Vitamin D + calcium | k=2, n=37,462 | RCT | Women only | Inconsistent | Moderate: older women from United States; results may not be applicable to men or younger age groups | Fair/Good | 1 trial109 showed a statistically significant decreased risk for developing any cancer while the other trial did not;108 no effect on CVD or mortality.
KQ 3 (efficacy) | Vitamin B_1_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Vitamin B_2_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Vitamin B_6_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Vitamin B_12_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Iron | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Zinc | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Magnesium | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Niacin | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Calcium + magnesium | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Folic acid + vitamin B_12_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 3 (efficacy) | Folic acid + vitamin B_6_ | k=0 | NA | NA | NA | NA | NA | No data
KQ 4 (harms) | Beta-carotene | k=6, n=112,820 | RCT | 1 trial discontinued early due to increased risk of lung cancer and related deaths | Consistent | Moderate-to-high: increased risk for lung cancer (smokers and/or asbestos-exposed workers), healthy male physicians or females from the United States; participants with a previous history of BCC and/or SCC | Good | Aside from paradoxical increase in lung cancer and related deaths among participants at high risk for lung cancer at baseline; no apparent serious harms from beta-carotene supplementation. Yellowing of skin frequently reported.
KQ 4 (harms) | Vitamin E | k=6, n=120,355 | RCT | | Consistent | Moderate-to-high: healthy men and women (general population or health care providers); individuals with hypercholesterolemia; male smokers in the United States | Good | Paradoxical effect on hemorrhagic stroke in 1 trial;80 mixed bleeding outcomes reported in other trials. No other apparent serious harms from vitamin E supplementation.
KQ 4 (harms) | Selenium | k=3, n=37,346 | RCT | One study discontinued early due to no treatment effects | Inconsistent | Moderate-to-high: healthy men and men with a previous SCC or BCC from the United States; elderly volunteers from the United Kingdom | Good | Mixed dermatological results; 1 study (NPC) found no dermatologic signs of toxicity while the other study (SELECT) found an increased risk of alopecia and mild dermatitis (p<0.01) with selenium supplementation; third trial found no serious harms (U.K. PRECISE).
KQ 4 (harms) | Vitamin A | k=5, n=127,998 | RCT (k=3), prospective cohort study (k=2) | 1 trial discontinued early due to increased risk of lung cancer and related deaths | Consistent | Moderate-to-high: all studies conducted in United States; 2 in all women, 2 in patients with a previous skin condition; 1 in heavy smokers or asbestos-exposed workers | Fair/Good | 2 studies in women reported negative impact on bone mass (i.e., increased risk of fractures); no other serious adverse events reported. Paradoxical effect for lung cancer and related death among participants at high risk for lung cancer at baseline (CARET).
KQ 4 (harms) | Folic acid | k=1, n=1,021 | RCT | Secondary analysis of prostate cancer cases in a study examining colorectal adenomas | NA | Low: recruited participants with a recent history of colorectal adenomas | Fair | Paradoxical effects on prostate cancer incidence; AFPPS did not report on other harms.101
KQ 4 (harms) | Vitamin D | k=2, n=5,420 | RCT | Includes a 2×2 factorial study of vitamin D and calcium | Consistent | Moderate: 1 study in older adults from the United Kingdom; other study in healthy young adults from Australia | Fair | No harms clearly associated with vitamin D supplementation; most attributed to calcium supplementation.
KQ 4 (harms) | Calcium | k=4, n=8,873 | RCT | Includes a 2×2 factorial study of vitamin D and calcium | Consistent | Moderate: older women from United States, United Kingdom, and New Zealand; results may not be applicable to men or younger age groups | Fair | Constipation and other digestive symptoms more frequently reported in calcium groups; renal events as well. Increased risk for hip fractures in calcium group (p=0.013), but not other sites.113
KQ 4 (harms) | Vitamin D + calcium | k=2, n=37,462 | RCT | Women only | Consistent | Moderate: older women from United States; results may not be applicable to men or younger age groups | Fair/Good | Increased risk of kidney stones reported in 1 trial;108 NSD between combination and placebo group on other harms.
KQ 4 (harms) | Iron | k=0 | NA | NA | NA | NA | NA | No data

† N randomized reported for entire study population.

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; BCC = basal cell carcinoma; CARET = Carotene and Retinol Efficacy Trial; CVD = cardiovascular disease; KQ = key question; MVI = multivitamin; NA = not applicable; NPC = Nutritional Prevention of Cancer; NSD = no significant difference; RCT = randomized, controlled trial; SCC = squamous cell carcinoma; SELECT = Selenium and Vitamin E Cancer Prevention Trial; U.K. PRECISE = U.K. Prevention of Cancer by Intervention with Selenium.

Another exception to this general conclusion are the two multivitamin studies, SU.VI.MAX and PHS-II (n=27,658), which found lower cancer incidence in men. Women were included only in SU.VI.MAX, which found a subgroup-specific benefit in men but not women (the interaction term was significant). When the data for men in these two studies were pooled, there was a statistically significant protective effect with multivitamin supplementation (unadjusted RR, 0.93 [95% CI, 0.87 to 0.99]; k=2; I^2^=0.0%). From this ratio, we calculate that one cancer case would be prevented if 98 men used a daily multivitamin for 11.2 years (in PHS-II, NNT=83) to 12.5 years (in SU.VI.MAX, NNT=131).

SU.VI.MAX was a good-quality trial with randomization stratified by sex, which strengthens the validity of the comparison by sex. PHS-II was also rated good quality, with a large sample size and long followup. The small size of the effect in PHS-II and the lack of an effect in women in SU.VI.MAX suggest caution in overgeneralizing these results. Additional studies are warranted given the widespread use of multivitamin supplements in the United States, but the need to recruit many participants and follow them for a decade or more creates a large barrier to such research.

The authors of SU.VI.MAX speculate that the observed sex difference in multivitamin effects on cancer incidence may have been due to lower baseline antioxidant status in men than women. A baseline difference, however, was found only for beta-carotene—baseline levels of vitamins E and C, selenium, and zinc were similar in men and women.49 Other behavioral or biological differences could modify the effects of antioxidant supplements on men and women, but with only one study showing the difference, speculation may be premature. Also, general scientific knowledge about sex-based biological differences is limited at best, since most basic cellular and molecular studies fail to consider or even identify the sex of the organism from which the study materials were derived.

While we provide pooled results for the multivitamin studies, direct comparison is made difficult by the design differences. PHS-II included a 32-component supplement, whereas the SU.VI.MAX supplement contained only five components. The mean age in PHS-II was 64 years and in SU.VI.MAX was 49 years. Men in PHS-II took the multivitamin for over 11 years on average, whereas active treatment in SU.VI.MAX ended at 7.5 years. At 7.5 years, the benefit on cancer incidence in SU.VI.MAX was larger (RR, 0.69) than in PHS-II (RR, 0.92), but the latter was at 11.2 years. The RR for men in SU.VI.MAX at 12.5 years was closer to that in PHS-II (0.91), but the proportion of men who continued assigned treatment is unknown. The possibly larger effect in SU.VI.MAX could be attributed to the younger age, but PHS-II found trends favoring older individuals (>70 years) for both cancer incidence and CVD.50,57

Other evidence for sex differences in the results presented in this review is limited. Many of the studies included only one sex and the results were rarely stratified by sex among studies with mixed populations. One study of vitamin D supplementation showed a statistically significant protective effect against colon cancer death in women (p=0.04) but not men (p=0.96).104 This analysis, however, was based on four deaths in the placebo group and none in the vitamin D group, so it is quite likely to be spurious (the sex interaction was not subjected to a formal test). When comparisons were made for other outcomes, no other sex differences were found.

One observational study, IWHS, addressed the question of multivitamin effects in postmenopausal women. IWHS was a good-quality longitudinal cohort study that began in 1986 and enrolled nearly 39,000 women.133 While we excluded mortality data from all observational studies in the main review, this cohort study provides worthwhile context. In 2011, IWHS investigators compared the use of any one of 15 supplements in the 15,594 women who died during followup with those who were alive. The IWHS investigators found a small but significant increase in mortality among the multivitamin users. While IWHS reports findings by individual supplement, the participants were in fact taking a variable mix of supplements, complicating interpretation.

One more exception to lack of effects in supplement users is the potential harms of daily beta-carotene supplementation (range, 30 to 50 mg) among individuals at high risk for lung cancer. Two included trials (ATBC and CARET) examining the effect of beta-carotene supplementation (either alone or in combination with another supplement) specifically recruited and enrolled current heavy smokers,59,60 asbestos-exposed workers, or both.60 These two trials found a statistically significant increased risk for lung cancer and lung cancer death at various followup times, which led one of these studies to stop early.60 Other beta-carotene studies stratified lung cancer incidence by smoking status after concerns were raised by the results from the ATBC trial and CARET. PHS-I found no statistically significant risk for developing lung cancer among current smokers (smoking level not reported) with beta-carotene supplementation (RR, 0.90 [95% CI, 0.58 to 1.40]).61 WHS was unable to conduct any meaningful analyses of site-specific cancers among current smokers (smoking level not reported) due to the small number of participants who reported smoking at baseline (13%). WHS, however, did not find a statistically increased risk of invasive cancer among those assigned to receive beta-carotene.62 While the difference in baseline lung cancer risk is the most likely explanation for the different outcomes in these studies, the dosage of the beta-carotene supplementation also differed. In the two trials in high-risk populations (ATBC and CARET), participants received 30 to 50 mg of beta-carotene daily, while in PHS-I and WHS, participants received 50 mg of beta-carotene every other day.

We identified a meta-analysis examining smoking status and the effect of beta-carotene on the incidence of lung cancer using pooled data from ATBC, CARET, PHS-I, and WHS.134 Among current smokers, beta-carotene supplementation was significantly associated with an increased risk of lung cancer (OR, 1.24 [95% CI, 1.10 to 1.39]; k=4), but there was no effect on former smokers. A recent Cochrane review also found that individuals taking beta-carotene with a risk for lung cancer had a statistically significant increased risk of lung cancer incidence (RR, 1.11 [95% CI, 1.01 to 1.21]; k=4), lung cancer mortality (RR, 1.18 [95% CI, 1.01 to 1.38]; k=2), and all-cause mortality (RR, 1.09 [95% CI, 1.05 to 1.13]; k=2); no effect was seen among those not at risk for lung cancer.135 No trend toward increased lung cancer incidence among individuals at high risk for lung cancer was seen in trials of supplements other than beta-carotene; there were also no significant effects on CVD, cancer, or mortality rates among those at high risk for lung cancer.

The effects of vitamin D and calcium, alone or in combination, on CVD and cancer were studied in five trials. Three trials provided data on calcium alone, but the results were mixed. RECORD and ACS showed some increase in CVD incidence, but ACS also showed a decrease in CVD mortality with calcium; none of the differences were significant. Cancer rates with calcium were lower in the Lappe study but higher in RECORD, and again neither difference was significant. Vitamin D plus calcium was specifically studied in two trials and the results were also mixed. Only one examined CVD incidence and found no effect. Both reported cancer outcomes and one smaller trial found a significant decrease in overall cancer incidence over 4 years, but the larger trial did not. Another trial (RECORD) examined vitamin D and calcium supplementation under a 2×2 factorial design and also found no effects with either supplementation. To further evaluate the independent effects of calcium on cancer, we reanalyzed the RECORD data comparing the calcium only arm to the placebo only arm (Appendix F Tables 4–6; Appendix F Figures 1 and 2). The point-estimate RRs were similar in the two analyses except, as expected, the CIs were wider in the calcium versus placebo comparison due to there being about half the number of events.

The simplest overall interpretation of the vitamin D and calcium results is that there is likely no effect on CVD or cancer. Wang and colleagues, in another systematic review of this topic, came to the same conclusion.120 The data suggest, however, that the effects of calcium on these endpoints may be different than the effects of vitamin D. Figure 4 shows the pooled analyses for all-cause mortality. There are only two vitamin D studies to pool, but together they show a trend toward lower mortality in the supplement groups (unadjusted RR, 0.94 [95% CI, 0.88 to 1.01]). In contrast, the point estimates for calcium are all greater than 1, though with large CIs. The lack of statistical significance makes this comparison speculative, but it does support the wisdom of conducting separate studies of calcium and vitamin D for the endpoints examined here.

In addition, several observers have recently raised the possibility of a harmful effect of calcium intake or supplementation on CVD outcomes. The ACS investigators have published two meta-analyses on calcium and CVD, in 2010^136^ and 2011.^137^ The 2011 meta-analysis includes some of the studies in the 2010 meta-analysis, plus a reanalysis of the WHI vitamin D and calcium study.111 These analyses concluded that calcium supplementation is associated with an increased risk of MI136 and perhaps stroke.137 There are a number of potential reasons that these papers came to a different conclusion than our analysis and that of Wang and colleagues. The 2010 meta-analysis included 15 studies, only three of which met our criteria for inclusion. The other 12 studies were quite heterogeneous; some were small trials that contributed fewer than 20 events, another did not publish CVD events but supplied them for the meta-analysis,138 and none were designed to examine CVD outcomes. Many lacked information on the adjudication of CVD events. The results of the meta-analysis were mainly driven by the three studies that were included in our review: ACS, RECORD, and CPPS; however, CPPS has not published CVD outcomes so we could not examine them. The results of pooled data from these three studies for any outcome must be interpreted cautiously because of their heterogeneity; ACS included healthy postmenopausal women, CPPS included men with a history of colorectal polyps, and RECORD included men and women with a history of fragility fracture.

The 2011 meta-analysis137 incorporates a reanalysis of the WHI results, with some of the studies included in their first meta-analysis. The reanalysis of the WHI data selected only the women who were not using calcium or vitamin D supplements at baseline. Such post hoc subgroup analyses can be misleading. Also, in the 2010 meta-analysis, the authors state that the increase in CVD was seen only in the subgroup that was above the median intake of calcium at baseline; thus, it is not clear why one would expect that in WHI the harms of calcium supplementation would be seen in the lower-intake subgroup and not the higher-intake group. Furthermore, the WHI investigators conducted their own reanalysis of their trial results, stratified by baseline supplement use, and added the results of their large observational study.112 They found no evidence of a harmful effect of calcium plus vitamin D on any CVD (or cancer) outcome in either the RCT or the cohort, both overall and in the subgroup not taking a supplement at baseline.

Other recent observational studies have also generated additional attention to the issue of harm from calcium supplementation. In 2013, Xiao and colleagues reported that calcium supplementation was associated with increased CVD deaths (RR, 1.20 [95% CI, 1.05 to 1.36]) in men but not women in the National Institutes of Health-AARP Diet and Health Study.139 In 2012, Li and colleagues reported some evidence of lower MI risk with higher intake of dietary calcium but a higher risk of MI in those who reported taking a calcium supplement compared with those who did not (RR, 1.86 [95% CI, 1.17 to 2.96]).140 Different results for dietary and supplemental calcium highlight the possibility of confounding in the supplement users. Overall, there is insufficient consistency in the recent observational studies to conclude that calcium supplementation is harmful, but the issue deserves additional study.

In general, the results of vitamin supplementation trials have been disappointing at best, despite having a solid mechanistic basis.141 One explanation for this could be that the physiological systems affected by vitamins and other antioxidant supplements are complex, so the effects of superphysiological doses of only one or a few components are generally ineffective or actually do harm.142 This possibility is compatible with the finding in this review that the best data for any salutary effects was for the two multivitamin trials, which used more physiologic doses of a wider variety of agents.

## Limitations in the Body of Evidence

Despite the fact that about half of the U.S. population reports the use of vitamin and mineral supplements, at an annual cost of over $11 billion, there are few studies to support the effectiveness of such supplements in decreasing CVD, cancer, or mortality rates.

Published studies used a wide variety of supplements, in different doses and with different objectives and populations. Frequently, the data on CVD and cancer were derived from secondary analyses; only a few trials were designed to study the effects of a supplement on CVD or cancer. For most supplements, there were too few studies or too much clinical heterogeneity to allow for valid pooling of outcomes, limiting the power to detect effects. The individual studies often had small sample sizes, and because many were focused on specific outcomes (e.g., fractures), the samples were not generalizable to the typical primary care population. Even some large trials, such as PHS-II, have limited generalizability because of the recruitment methods. In PHS-II, all participants were male physicians and only 5 percent of those contacted participated. Another limitation is the short duration of most trials (around 5 years) relative to the long preclinical development of both CVD and cancer. The trials may have been simply too short to detect effects. On the other hand, it could be argued that 5 years of use is as long term as most of the general public will accept. We did not identify any studies examining the efficacy for CVD or cancer prevention of calcium in combination with magnesium, folic acid in combination with vitamin B_12_, folic acid in combination with vitamin D_6_, niacin, iron, magnesium, zinc and vitamins B_1_, B_2_, B_6_, and B_12_. We did not identify any studies examining the safety of iron supplementation and the few included trials that reported harms did so comprehensively.

Two additional design issues complicated our analysis. Several of the trials used factorial designs (2×2 or more complex combinations). Such designs are appealing because the ability to collapse across one intervention in analyzing another effectively doubles the sample size for each intervention. However, such analysis assumes that there is no biological interaction between the two interventions, and a formal statistical interaction test should be included in the first step of the analysis. If an interaction is present, then only the simple main effects may be examined (i.e., to examine factor A, only individuals in the factor B placebo condition may be used). Unfortunately, such tests for interaction are often overlooked, and even when done may be underpowered, unless the interaction effect is very large. Furthermore, in nutrition trials many nutrients would be expected to interact biologically (e.g., two antioxidant supplements). Most of the factorial supplement studies included in this report reported on interaction tests and found none (SELECT was an exception, finding that cosupplementation with selenium erased the modest increased risk of prostate cancer seen in the vitamin E only group).143 A discussion of the power issue was rare. Given the presumed biology behind these supplements, the lack of significant interactions supports the likelihood of little or no true effect.

A related design limitation is the inflation of type I error introduced by multiple testing. As noted, most of the studies were not designed to test hypotheses about CVD and cancer prevention. Secondary analyses, especially when subgroups are involved, can be problematic in general, and when they include tests for treatment differences on multiple outcomes, the likelihood of a type I error increases. For example, several studies examined site-specific cancer incidence as secondary analyses, without any correction of the significance values for the number of tests.

Most of the trials were conducted in populations of European ancestry, so the results may not be generalizable to other race/ethnicity groups. While there is no a priori reason to believe that the biology that these supplements might affect differs across racial/ethnic groups, the differences in other risk factors for CVD and cancer (e.g., nutritional, physical activity, or socioeconomic circumstances) among these groups in the United States could affect the outcomes.

## Limitations in Our Approach

While this systematic review considered a broad range of studies and supplements, it was also focused in important ways. We considered only primary prevention interventions in generally healthy people, excluding secondary prevention trials aimed only at the disease in question and tertiary prevention or treatment studies. In some cases, however, we included secondary prevention studies if the supplement was also intended to prevent other relevant disease that was not present at baseline, mortality, or both (e.g., SCPS examined the efficacy of supplementation to prevent other cancers in patients with a previous BCC or SCC). We also excluded studies in which participants had active CVD and/or cancer at baseline.

We excluded studies of individuals with nutritional deficiencies. This criterion eliminated the Linxian study, a large multivitamin trial in China that included individuals with baseline nutritional deficiency.144 The Linxian study, which supports the use of multivitamin supplements, has been included in previous reviews of this topic, as have secondary prevention trials. We also focused on supplement doses that were below the recommended upper limit (or so-called “nutritional doses”), so our results do not pertain to high-dose vitamin or mineral therapy, which in any case should be treated as a pharmacological intervention.

We also excluded studies that did not include CVD, cancer, or all-cause mortality as an a priori aim of the study (whether primary or secondary). The purpose of this exclusion criterion was to focus on studies designed to assess the questions posed for this review. As noted previously, post hoc analyses of secondary outcomes are more subject to biased or chance findings, but many other systematic reviews and meta-analyses have included such studies in their assessment of outcomes. Note that if we included a trial designed to answer one of the outcomes, we also report analyses of secondary outcomes as long as there was some indication that these analyses were planned at baseline.

Our definition of a multivitamin as containing three or more supplements was arbitrary. Even this inclusive definition included only two trials for efficacy. However, those two trials studied very different supplements: five components in SU.VI.MAX. and 32 in PHS-II. Since only the former trial included women, it could be argued that there are no data on a “true” multivitamin in women. The SU.VI.MAX supplement included agents expected to improve both inflammation and oxidative stress and showed benefit for cancer incidence in men, matching the PHS-II results, so the importance of this difference is debatable.

The number of supplements included in this review also presented a challenge for reporting on harms. A very large number of adverse events may be included, especially from observational studies, where the unexposed group may not be comparable with the exposed group. Instead we took a narrower approach by examining harms in the randomized trials primarily. We also limited the analysis of mortality results to RCTs.

This is a review of randomized clinical trials, a design that was created primarily to evaluate drug therapy. It can be argued that the typical implementation of this design is not ideally suited to evaluating nutrients rather than drugs.145 In placebo-controlled trials of medications, the control group is not exposed to the medication. In a nutrient supplementation study, however, the control group is exposed to some level of the agent under study. The question is different: is an optimal level of exposure to the nutrient better than the usual level? To conduct such a study implies that both the usual level of exposure and the optimal level are known. Different levels of exposure are also possible in drug trials, of course, but most drug RCTs for efficacy are preceded by dosing studies that define the “best” dose. Thus the threat of an insufficient difference between the exposure in the treatment and control groups is greater for a nutrient study. Lappe and Heaney cite the example of the WHI calcium and vitamin D study.145 When that study was designed, average calcium intake was about half of what was observed in the actual control group; the subsequent increase in average calcium intake narrowed the dose difference between groups and may have created a control group that had already achieved all the benefit possible from calcium intake. Similarly, the dose of vitamin D in WHI was lower than many now think is necessary to achieve adequate blood levels, although there is still great uncertainty about the optimal level. We are not arguing that RCTs of nutritional supplements are invalid; such studies do indeed test the effects of the supplement versus no supplement, but changes in average intake (in the control group) are an additional threat to these studies compared with drug studies.

Finally, by focusing our review on nutrient supplementation to improve nutritional status in generally replete adults, the targeted use of nutrients in deficient or higher-risk individuals was not completely addressed. Our results are consistent with potential benefit of higher doses in those with suboptimal nutrient status. For example, Lappe and colleagues' vitamin D and calcium study found some evidence of a benefit on cancer using a relatively high dose of vitamin D (1,000 IU/d) in a population known to have low average vitamin D levels.109 Similarly, the effects of selenium seen in the NPC study89 was confined to participants with low baseline selenium levels.

## Applicability

The purpose of this review was to describe the evidence of benefit on cancer and CVD morbidity and mortality from vitamin and mineral supplementation in generally healthy, nutritionally-replete adults. Only two included trials directly addressed these questions in the intended population. One used a more typical multiple vitamin and mineral formulation but was limited to predominately white male physicians50 and the other recruited a general population but used a supplement with just five ingredients.49 Thus, even these studies have somewhat limited applicability in underrepresenting women and nonEuropean populations. Since SU.VI.MAX found an effect only in men, the lack of another study in women is particularly limiting.

All of the other trials included in the review used only one or two nutrients, with limited numbers of studies for each. Few of these studies were designed to test effects on cancer or CVD endpoints, and many enrolled selected populations, populations with unrelated disease such as cataracts (we excluded secondary prevention studies), or smokers. Most of the calcium and vitamin D studies were directed at fracture prevention. The applicability of these targeted populations to the general population is thus limited, though not absent, particularly when viewed together.

In addition, the majority of included studies specifically recruited middle-aged (45 to 64 years) and older adults (≥65 years); therefore, the body of evidence included in this review is most applicable to these populations. Children and younger adults are not represented in these studies. With older age comes a greater risk for CVD, cancer, and mortality. As a result, we can expect higher numbers of these events in older age groups and any subgroup analyses that show an increase in these outcomes with older age should be interpreted cautiously. Correspondingly, one might expect a potentially larger benefit in preventing these health outcomes with vitamin and/or mineral supplementation in older populations who may be less nutritionally replete than younger age groups. When examined in post hoc subgroup analyses, some studies found small but statistically significant differences between older and younger subgroups on outcomes,57 but overall, there were few differences by age within studies.

## Future Research

Our review highlights a series of evidence gaps. Despite there being two relatively large trials examining the efficacy of a multivitamin in the primary prevention of CVD and cancer in a general population, population selection and potential sex-specific findings limit the applicability of their results. Clearly, there is a large knowledge gap on the effects of multivitamins on CVD, cancer, and many other endpoints. To study this question, future trials should recruit from a general population with representation of multiple minority groups and both sexes, employ a multivitamin that is reasonably similar to the popular brands in the current market, and include enough participants to provide adequate power to detect benefits and harms. This is a tall order, and any such study would still face difficulties. Agreement on the content of the multivitamin would likely be difficult to achieve, so the results of the trial might be dismissed by observers who felt that an important ingredient was omitted. The wide availability of multivitamins could result in significant crossover. The large number of participants and long followup needed would result in an expensive trial. It is doubtful that any multivitamin manufacturer would see the wisdom of supporting such a trial, making it more difficult to fund. Still, the U.S public is devoting significant resources to multivitamins, so such a trial could have significant public health benefit, whatever the outcome.

Despite its limitations, the current literature on single or paired vitamins and minerals is sufficient to discourage additional studies of beta-carotene; vitamins A, C, or E; and folic acid in general populations or especially among those at high risk of the endpoint and not deficient in the nutrient to be supplemented. Future studies of selenium would need to clearly separate individuals with adequate and low baseline selenium levels. Vitamin D and calcium are currently indicated for fracture prevention but their effects on other endpoints are unclear. Despite their close relationship on bone health, future studies would be better if vitamin D and calcium were studied separately, as they may have different effects; in particular, calcium alone may have harmful effects on CVD. At least six studies of vitamin D alone are in process; no ongoing study of calcium alone was identified. Such studies should include fracture outcomes as well, since it will be necessary to balance benefits on bone health against any harms for CVD, cancer, or mortality.

The points made by Lappe and Heaney in their recent article are relevant to additional studies of nutritional supplements.145 Unlike drug studies, control groups in nutrient studies are also exposed to the agent under investigation. Careful thought needs to be given to the biology of the nutrient and current understanding of average and presumed optimal levels. A broad diet that includes adequate plant-based foods is likely to supply sufficient nutrients for health in the general population. Supplements may be warranted if the actual diet strays from the natural diet or other factors come into play (e.g., reduced sun exposure lowering vitamin D levels). Measurement of exposure in both treatment and control groups would likely help with the interpretation of the diet, and some supplements may be reserved for individuals with known low levels, when these can be measured. Controlled clinical trials are indicated when there is equipoise toward the benefits and harms of the agent to be studied; this point can be hard to discern (and may be fleeting) for any study, but for nutrient supplements it may be particularly difficult to define when a trial is needed. Sometimes trials should be delayed if the biological understanding of a nutrient's role in health is evolving.

We did not identify any studies examining the efficacy for CVD or cancer prevention of calcium in combination with magnesium, folic acid in combination with vitamin B_12_, folic acid in combination with vitamin B_6_, niacin, iron, magnesium, zinc, and vitamins B_1_, B_2_, B_6_, and B_12_. We did not identify any studies examining the safety of iron supplementation. Future studies of these nutrients may be useful, keeping in mind the cautions of the previous paragraph.

We identified 11 relevant ongoing trials in healthy adults through national and international clinical trial registries. Each study listed cancer, CVD, mortality, or harms as primary or secondary outcomes (Appendix C). These trials are evaluating single or paired vitamins and minerals, including vitamin D alone or in combination with calcium (n=8), selenium with or without vitamin E (n=2), and vitamin C (n=1). We did not identify any published ongoing studies of multivitamins or other supplements in children, so this could be an important area for future research.

## Conclusions

For most of the supplements addressed in this report, we found no evidence of an effect of nutritional doses on CVD, cancer, or mortality in healthy individuals with a generally adequate diet. In most cases there are insufficient data to draw any conclusion. One exception in this report are the two multivitamin studies, SU.VI.MAX and PHS-II, which both found lower overall cancer incidence in men. While these trials were both methodologically rated as good, the lack of effect (and limited data) on women in SU.VI.MAX, the modest effect in men in both trials, and the lack of any effect in either study on CVD makes it difficult to recommend that supplementation with any vitamin will provide protection against CVD or cancer. Another exception are the two beta-carotene trials among individuals at high risk for lung cancer, which found a statistically significant increased risk of developing and dying from lung cancer.

Adequate dietary intake of calcium and vitamin D is necessary for bone health and to prevent osteoporosis and fracture.8 Supplementation with calcium and vitamin D have long been advocated to insure adequate intake, especially in postmenopausal women. However, in February 2013 the USPSTF recommended against supplementation with 400 IU or less of vitamin D or 1,000 mg or less of calcium for fracture prevention.146 In addition, existing data are compatible with the possibility that vitamin D and calcium have different effects on CVD and all-cause mortality. Future studies of calcium and vitamin D directed at CVD prevention should separate the effects of these two nutrients, and careful attention to dose is needed.

Few harms were identified in the included trials and observational cohort studies. There was no consistent pattern within each nutrient group and few people discontinued vitamin use due to adverse effects. This finding is consistent with the use of nutrients only within RDA amounts. The one exception is the association of beta-carotene supplements with increased lung cancer in trials of individuals exposed to tobacco smoke or asbestos. This finding, however, was not seen in other beta-carotene trials not restricted to high-risk individuals.