# Results

## Literature Search

Our literature search yielded 12,766 unique citations. From these, we provisionally accepted 277 articles for review based on titles and abstracts (Appendix B Figure 1). After screening the full-text articles, we judged 26 studies (103 articles) to have met the inclusion criteria. We excluded the remaining 174 full-text articles (Appendix D).

## KQ 1 What Is the Efficacy of Multivitamin Supplement Use on Health Outcomes in the General Adult Population?

## KQ 2 What Is Known About the Safety of Multivitamin Supplement Use in the General Adult Population?

### Summary of Results

We identified four good-quality RCTs (n=28,607)49-52 and one good-quality cohort study (n=72,337)53 that evaluated the health effects of a multivitamin supplement (Table 8; Appendix E Tables 1 and 2); studies varied in which nutrients were included in the multivitamin formulation and their dosages (Table 9), as well as in the duration of supplement use and outcomes evaluated. No impact on all-cause mortality was found in any of the three RCTS reporting this outcome: the Supplementation in Vitamins and Mineral Antioxidants Study (SU.VI.MAX),49 the Physician's Health Study II (PHS-II),50 or the Roche European American Cataract Trial (REACT).51 In REACT, which included 297 elderly European men and women, there were more deaths reported in the intervention group (n=9) than in the control group (n=3) after 3 years, but this difference was not statistically significant (p=0.07). When these data were pooled, there was no effect on all-cause mortality (unadjusted RR, 0.95 [95% CI, 0.81 to 1.11]), even in a sensitivity analysis with REACT removed (unadjusted RR, 0.95 [95% CI, 0.89 to 1.01]; data not shown).

Table 8 Multivitamin Evidence Summary

Study Quality | Study design Followup (max) | Supplement^*^ and treatment duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
SU.VI.MAX49,54-56,58,151-153 Good | RCT 13 years | Multivitamin 7.5 years (median) | 13,017 | 49 | 59 | Any: ↔ MI: NR Stroke: NR | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: ↔ Other: ↔ | ↔ | ↔ | Protective effect against cancer in men (↓) but not women (↔)
PHS-II50,57,154 Good | 2×2×2×2 factorial RCT 11.2 years | Multivitamin 11.2 years (median) | 14,641 | 64 | 0 | Any: ↔ MI: ↔^†^ Stroke: ↔ | Any: ↓ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: NA Other: ↔ | ↔ | ↔ | Minor side effects (↔), rashes (↑), and bleeding (↑)
REACT51 Good | RCT 3 years | Multivitamin 3 years | 297 | 66 | 59 | NA | NA | ↔ | ↔
Graat 2002^52^ Good | 2×2 RCT 1.3 years | Multivitamin (alone or in combination with vitamin E 200 mg) 1.3 years | 652 | 73 | 50 | NA | NA | NA | ↔ | Acute respiratory infections (↔)
NHS53 Good | Prospective cohort 18 years | Multivitamin NR | 72,337 | 58 | 100 | NA | NA | NA | ↑ | Hip fractures among current and former multivitamin users (↑)

* See Table 10 for vitamin and mineral components and their dosages for each study.

† Decreased risk for fatal myocardial infarction (p=0.048).

‡ Statistically significant protective effect for any cancer in men but not women.

Abbreviations: CRC = colorectal cancer; CVD = cardiovascular disease; MI = myocardial infarction; NA = not applicable; NHS = Nurses' Health Study; NR = not reported; PHS-II = Physician's Health Study II; RCT = randomized, controlled trial; REACT = Roche European American Cataract Trial; SU.VI.MAX = Supplementation in VItamins and Mineral Antioxidants Study; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

Table 9 Vitamin and Mineral Components of the Multivitamin Studies

Vitamin/mineral | SU.VI.MAX49 | PHS-II50 | REACT51 | Graat52 | NHS53
Not described | | | | | X
Beta-carotene | 6 mg | * | 6 mg | 1.2 mg
Biotin | | 30 mcg | | 150 mcg
Boron | | 150 mcg
Calcium | | 200 mg | | 74 mg
Chloride | | 72.6 mg
Chromium | | 130 mcg | | 25 mcg
Copper | | 2 mg | | 1.0 mg
Folic acid | | 400 mcg | | 200 mcg
Iodine | | 150 mcg | | 100 mcg
Iron | | 4 mg | | 4.0 mg
Magnesium | | 100 mg | | 30 mg
Manganese | | 3.5 mg | | 1.0 mg
Molybdenum | | 160 mcg | | 25 mcg
Niacin | | 20 mg
Nickel | | 5 mcg
Pantothenic acid | | 10 mg
Phosphorus | | 48 mg | | 49 mg
Potassium | | 80 mcg
Riboflavin | | 1.7 mg
Selenium | 100 mcg | 20 mcg | | 25 mcg
Silicon | | 2 mg | | 2 mcg
Thiamin | | 1.5 mg
Vanadium | | 10 mcg
Vitamin A | | 5,000 IU | | 600 mg
Vitamin B_1_ | | | | 1.4 mg
Vitamin B_12_ | | 25 mcg | | 1 mcg
Vitamin B_2_ | | | | 1.6 mg
Vitamin B_3_ | | | | 18 mg
Vitamin B_5_ | | | | 6 mg
Vitamin B_6_ | | 3 mg | | 2.0 mg
Vitamin C | 120 mg | 60 mg | 250 mg | 60 mg
Vitamin D | | 400 IU | | 5 mcg
Vitamin E | 30 mg | 45 IU | 200 mg | 10 mg
Vitamin K | | 10 mcg | | 30 mcg
Zinc | 20 mg | 15 mg | | 10 mg

* 40% was supplemented with vitamin A.

In the two RCTs reporting CVD and cancer outcomes (SU.VI.MAX and PHS-II), multivitamins had no impact on most types of fatal and nonfatal CVD events, and the small benefit for fatal MI with supplementation reported in one trial (PHS-II) could be a type I error due to multiple testing. In contrast, both trials suggested a small reduction in overall cancer incidence in men after 11.2 to 12.5 years of followup. The age-adjusted HR for total cancer was 0.92 (95% CI, 0.86 to 0.998) among 14,641 male physicians older than age 50 years taking Centrum Silver® (Pfizer, Kings Mountain, NC) after 11.2 years of followup.50 In a general population of middle-aged adults (n=13,017), SU.VI.MAX indicated no impact on overall cancer from a five-component multivitamin formulation after an initial followup of 7.5 years and posttreatment followup of an additional 5 years.54 However, based on a significant sex-by-treatment group interaction (p=0.02), a sex-specific subgroup analysis showed a protective effect on any cancer (RR, 0.69 [95% CI, 0.53 to 0.91]) among men, but not women.

No consistent evidence of harms from nutritional dosages of multivitamins emerged from four RCTs50-52,55 and a cohort study (Nurses' Health Study [NHS]),53 although the possible harms from supplementation reported in individual studies or in subgroup analyses (e.g., increased melanomas among women enrolled in SU.VI.MAX, trend toward increased death among the REACT antioxidant group) warrant additional research.

### Study Details

SU.VI.MAX was a double-blind, placebo-controlled RCT designed to test the hypothesis that daily supplementation with antioxidant vitamins and minerals reduced the incidence of major health problems, particularly CVD and cancer.54 SU.VI.MAX supplements used “nutritional” doses (one to three times the RDA) of vitamin C (120 mg), vitamin E (30 mg), and beta-carotene (6 mg), plus selenium (100 mcg) and zinc (20 mg). Randomization was stratified by sex and age, and baseline characteristics were balanced between groups. Adherence to the medication was high (>70%) and comparable in both groups. We rated the overall quality of the study as good.

SU.VI.MAX recruited a general adult population in France, including men ages 45 to 60 years and women ages 35 to 60 years who were basically healthy and not taking a supplement containing any of the study agents. Recruitment was through a national public media campaign in 1994; almost 80,000 people responded, of which 21,481 returned a questionnaire and 14,412 were eligible. The 13,017 participants randomized into the trial had a mean age of 49 years; 59 percent were women. SU.VI.MAX reported its primary outcomes at the end of the active intervention phase of the trial (7.5 years after randomization).49 Although it no longer provided supplements, SU.VI.MAX reported primary outcomes again 5 years later (12.5 years after randomization).56

PHS-II was a randomized, double-blind, placebo-controlled trial testing the effects of a multivitamin on CVD and cancer. PHS-II employed a 2×2×2×2 factorial design to test the effects of vitamin E, vitamin C, and beta-carotene, as well as a multivitamin. Results from two other arms of this trial are included in KQs 2 and 4. PHS-II used a multivitamin widely marketed in the United States (Centrum Silver) that contained 32 ingredients. The full list of ingredients appears in Table 9. Except for vitamins E and B_12_, the doses did not exceed the RDA.

PHS-II recruited in two phases. In the first, 18,763 men from PHS-I were invited to participate, of which 7,641 were eligible and willing and were randomized. In the second phase, 254,597 additional physicians were contacted, of which 42,165 completed a baseline questionnaire and 7,000 were randomized.50 Randomization was concealed and stratified by 5-year age group, prior history of CVD or cancer, and previous assignment to beta-carotene (for PHS-I participants). Baseline characteristics were balanced. All participants were male physicians, with a mean age at baseline of 64 years. Followup was greater than 98 percent and self-reported adherence was above 70 percent through 8 years of followup and 67 percent at the end of the trial, without differences by group. We rated the overall quality of the study as good.

The other two multivitamin RCTs provided data on all-cause mortality and/or harms. REACT was a good-quality RCT that used a combination of three antioxidants (vitamin C [250 mg], vitamin E [200 mg], and beta-carotene [6 mg]) to prevent progression of early age-related cataracts in 297 men and women (mean age, 66.2 years).51 Similarly, the study by Graat and colleagues was a small, good-quality RCT included for harms only. It evaluated the efficacy of a 26-component multivitamin supplement (components listed in Table 9) to reduce the incidence and severity of acute respiratory infections in older adults (n=652; mean age, 73.2 years).52 It also included a vitamin E (200 mg) supplement in a 2×2 factorial design. A single good-quality prospective cohort study (NHS) among 72,337 postmenopausal registered nurses (mean age, 58.3 years) provided additional data regarding harms.53 It evaluated the relationship of vitamin A intake in multivitamins and the risk of hip fractures.

### CVD

Two trials (n=27,658) reported CVD outcomes (Table 10, Figure 2).49,57 Primary cardiovascular outcomes reported in SU.VI.MAX (n=13,017) included major fatal and nonfatal ischemic cardiovascular events. Overall, there was no effect on ischemic CVD events after 7.5 years of supplementation; incidence was 2.1 percent in both arms (RR, 0.97 [95% CI, 0.77 to 1.20]). Although the RR was lower in men, it was not statistically significant, and the sex-by-group interaction was also not significant (p=0.44). The results after an additional 5 years of followup (without further provision of the vitamins) were almost identical (RR, 0.97 [95% CI, 0.80 to 1.17]). SU.VI.MAX did not report on the incidence of diabetes mellitus.

Table 10 Cardiovascular Disease Incidence and Mortality Among Multivitamin Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with event (%) | Comparator, # of subjects with event (%) | RR or HR | 95% CI | P-value
Ischemic CVD incidence^*^ | SU.VI.MAX49,56 | MVI vs. placebo | 7.5 | 134/6,481 (2.1) | 137/6,536 (2.1) | 0.97^†^ | 0.77 to 1.20 | 0.80
Ischemic CVD incidence^*^ | SU.VI.MAX49,56 | MVI vs. placebo | 12.5 | 222/6,481 (3) | 224/6,539 (4) | 0.97^†^ | 0.80 to 1.17 | 0.73
Any CVD incidence^‖^ | PHS-II57 | MVI vs. no MVI | 11.2 | 876/7,317 (12) | 856/7,324 (11.7) | 1.01^‡^ | 0.91 to 1.10 | 0.91
MI incidence | PHS-II57 | MVI vs. no MVI | 11.2 | 317/7,317 (4.3) | 335/7,324 (4.6) | 0.93^‡^ | 0.80 to 1.09 | 0.39
Stroke incidence | PHS-II57,§ | MVI vs. no MVI | 11.2 | 332/7,317 (4.5) | 311/7,324 (4.2) | 1.06^‡^ | 0.91 to 1.23 | 0.48
Any CVD death | PHS-II57 | MVI vs. no MVI | 11.2 | 408/7,317 (5.6) | 421/7,324 (5.7) | 0.95^‡^ | 0.83 to 1.09 | 0.47
Fatal MI | PHS-II57 | MVI vs. no MVI | 11.2 | 27/7,317 (0.4) | 43/7,324 (0.6) | 0.61^‡^ | 0.38 to 0.995 | 0.048
Fatal stroke | PHS-II57 | MVI vs. no MVI | 11.2 | 89/7,317 (1.2) | 76/7,324 (1.0) | 1.16^‡^ | 0.85 to 1.58 | 0.34

* Includes fatal and nonfatal ischemic CVD events.

† RR adjusted by age and sex unless otherwise noted.

‡ HR adjusted by age, study cohort, beta-carotene assignment, and vitamin E and C assignment and stratified by CVD at baseline.

§ Ischemic and hemorrhagic stroke reported separately, no significant difference between groups for either outcome.

‖ Includes nonfatal MI, nonfatal stroke, and CVD death.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; MVI = multivitamin; PHS-II = Physician's Health Study II; RR = relative risk; SU.VI.MAX = Supplementation in VItamins and Mineral Antioxidants Study; y = years.

The primary CVD outcomes reported in PHS-II were any major cardiovascular event, including nonfatal MI, nonfatal stroke, and CVD mortality. PHS-II also found no effect on CVD after 11.2 years of followup, with 12 percent incidence of any CVD in both arms (HR, 1.01 [95% CI, 0.91 to 1.10]).57 There were also no statistically significant differences between groups on the number of participants with an MI and stroke (any, ischemic, or hemorrhagic). There was also no statistically significant difference in the number of CVD-related deaths (HR, 0.95 [95% CI, 0.83 to 1.09]). The number of fatal MIs, however, was borderline statistically significant (p=0.048) in favor of the intervention. There was no adjustment, however, for multicomparisons.

### Cancer

Two trials (n=27,658) reported cancer outcomes (Table 11, Figure 3).49,50 The primary cancer outcome for SU.VI.MAX was incident cancer of any kind (except BCC of the skin). There was no significant difference between groups for overall cancer incidence (RR, 0.90 [95% CI, 0.76 to 1.06]). The results, however, differed by sex. A significant sex-by-group interaction was observed (p=0.02), with a protective effect of the multivitamin in men (p=0.008) but no effect in women (p=0.53). For men, the RR of any cancer was 0.69 (95% CI, 0.53 to 0.91), while for women, the RR was 1.04 (95% CI, 0.85 to 1.29). It is possible that effects were only seen in men in SU.VI.MAX because they were older than the women (mean age, 51.3 years in men vs. 46.6 years in women).

Table 11 Cancer Incidence and Mortality Among Multivitamin Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with event (%) | Comparator, # of subjects with event (%) | RR or HR | 95% CI | P-value
All cancer sites incidence | SU.VI.MAX49,55,56 | MVI vs. placebo | 7.5 | 267/6,481 (4.1) | 295/6,536 (4.5) | 0.90^†^ | 0.76 to 1.06 | 0.19
All cancer sites incidence | SU.VI.MAX49,55,56 | MVI vs. placebo | 12.5 | 490/6,481 (7.5) | 511/6,536 (7.8) | 0.93^†^ | 0.82 to 1.05 | NSD
All cancer sites incidence | PHS-II50 | MVI vs. no MVI | 11.2 | 1,290/7,317 (17.6) | 1,379/7,324 (18.8) | 0.92^*^ | 0.86 to 0.998 | 0.04
Breast cancer incidence | SU.VI.MAX49,55,56 | MVI vs. placebo | 7.5 | 95/3,859 (2.5) | 100/3,820 (2.6) | NR | NR | NR
Prostate cancer incidence | SU.VI.MAX49,55,56 | MVI vs. placebo | 8.9 | 49/2,569 (1.9) | 54/2,572 (2.1) | 0.88^‡^ | 0.60 to 1.29 | NSD
Prostate cancer incidence | PHS-II50 | MVI vs. no MVI | 11.2 | 683/6,988 (9.8) | 690/6,992 (9.9) | 0.98^*^ | 0.88 to 1.09 | 0.76
Colorectal cancer incidence | PHS-II50 | MVI vs. no MVI | 11.2 | 99/7,255 (1.4) | 111/7,264 (1.5) | 0.89^*^ | 0.68 to 1.17 | 0.39
Lung cancer incidence | PHS-II50 | MVI vs. no MVI | 11.2 | 74/7,300 (1.0) | 88/7,310 (1.2) | 0.84^*^ | 0.61 to 1.25 | 0.26
Any cancer death | PHS-II50 | MVI vs. no MVI | 11.2 | 403/7,317 (5.5) | 456/7,324 (6.2) | 0.88^*^ | 0.77 to 1.01 | 0.07
Prostate cancer death | PHS-II50 | MVI vs. no MVI | 11.2 | 70/7,317 (1.0) | 78/7,324 (1.1) | 0.91^*^ | 0.66 to 1.26 | 0.58
Colorectal cancer death | PHS-II50 | MVI vs. no MVI | 11.2 | 37/7,317 (0.5) | 39/7,324 (0.5) | 0.95^*^ | 0.60 to 1.48 | 0.81
Lung cancer death | PHS-II50 | MVI vs. no MVI | 11.2 | 65/7,317 (0.9) | 73/7,324 (1.0) | 0.89^*^ | 0.64 to 1.25 | 0.50

* HR adjusted by age, study cohort, and randomized treatment assignment; stratified by baseline cancer.

† RR adjusted by age and sex unless otherwise noted.

‡ HR, adjustment not reported.

Abbreviations: CI = confidence interval; HR = hazard ratio; MVI = multivitamin; NR = not reported; NSD = no significant difference; PHS-II = Physician's Health Study II; RR = relative risk; SU.VI.MAX = Supplementation in VItamins and Mineral Antioxidants Study; y = years.

SU.VI.MAX also reported cancer incidence by cancer type. The multivitamin supplement had no effect on the incidence of hematological, thyroid, urinary tract, genital, respiratory tract, digestive tract, or oral cavity cancer, but tended toward very small, nonsignificant benefits for sex-specific cancers (i.e., prostate and breast) and possible sex-specific harms for skin cancer (data not shown).49 After a followup of almost 9 years, prostate cancer occurred in 103 men: 49 in the supplement arm and 54 in the control group (p-value not significant).55 Similarly, in women, there were five fewer breast cancers in the intervention group. After 7.5 years of followup, 157 skin cancers (i.e., melanoma at any stage, BCC, SCC, and other types of skin cancer) occurred overall; incidence was higher in women in the supplement arm (p=0.03), but not in men.58 Most of this difference was due to higher rates of melanoma; the HR of melanoma for women taking supplementation was 4.31 (95% CI, 1.23 to 15.13). Deaths by cancer type were not reported.

PHS-II was designed to evaluate both overall and site-specific cancer rates in men (excluding nonmelanoma skin cancer [NMSC]).50 After 11.2 years of followup, all-site cancer incidence was significantly reduced in the intervention group (17.6%) compared with the comparison group (18.8%) (HR, 0.92 [95% CI, 0.86 to 0.998]). Prostate, colorectal, lung, bladder, and pancreatic cancer, as well as lymphoma, leukemia, and melanoma incidence did not differ by intervention group in PHS-II. Cancer mortality did not differ by treatment, although it showed a trend favoring the intervention (HR, 0.88 [95% CI, 0.77 to 1.01]). There were no statistically significant effects on prostate, colorectal, lung, pancreatic, or other cancer (e.g., bladder) deaths; however, death rates for these cancers were uniformly lower in those taking the multivitamin supplement (Table 11).

When data from the two studies were pooled, the cancer incidence was significantly lower among men in the supplement groups (unadjusted RR, 0.93 [95% CI, 0.87 to 0.99]; I^2^=0.0%; data not shown).

### All-Cause Mortality

All-cause mortality (Table 12, Figure 4) was reported in three trials (n=27,955).49-51 In SU.VI.MAX, overall mortality was lower in the supplement group, but the difference was not significant (RR, 0.77 [95% CI, 0.57 to 1.00]) after 7.5 years of followup. Mortality was significantly lower in men (RR, 0.63 [95% CI, 0.42 to 0.93]) but not in women (RR, 1.03 [95% CI, 0.64 to 1.63]). The sex-by-group interaction, however, was not significant (p=0.11).49 The mortality rate was higher in PHS-II participants, who were much older, but the RR reduction was much smaller than for men in SU.VI.MAX (HR, 0.94 vs. RR, 0.63, respectively) and was not statistically significant (p=0.13) (note that the followup time was shorter in SU.VI.MAX). When data from the two studies were pooled, multivitamins did not have a statistically significant effect on all-cause mortality in men (RR, 0.94 [95% CI, 0.88 to 1.01]; I^2^=37.9%; data not shown). There were only 12 deaths in REACT (n=297).51 Nine deaths occurred in the treatment group and three in the control group (p=0.07), but these data are likely unreliable given the small number of deaths. When data from the three studies were pooled (Figure 4), there was no statistically significant effect on all-cause mortality with multivitamin supplementation (unadjusted RR, 0.95 [95% CI, 0.80 to 1.11]; I^2^=42.5%), even with a sensitivity analysis removing REACT (unadjusted RR, 0.95 [95% CI, 0.89 to 1.01]; data not shown).

Table 12 All-Cause Mortality Among Multivitamin Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR or HR | 95% CI | P-value
SU.VI.MAX49,56 | MVI vs. placebo | 7.5 | 76/6,481 (1.2) | 98/6,536 (1.5) | 0.77^*^ | 0.57 to 1.00 | 0.09
SU.VI.MAX49,56 | MVI vs. placebo | 12.5 | 156/6,481 (2.4) | 178/6,536 (2.7) | 0.87^*^ | 0.70 to 1.04 | 0.19
PHS-II50 | MVI vs. no MVI | 11.2 | 1,345/7,317 (18.4) | 1,412/7,324 (19.3) | 0.94^†^ | 0.88 to 1.02 | 0.13
REACT51 | MVI vs. placebo | 3 | 9/149 (6) | 3/148 (2) | NR | NR | 0.07

* Adjusted by age and sex unless otherwise noted.

† HR adjusted for age, study cohort, and randomized assignment (beta-carotene, vitamin E, and vitamin C) and stratified by baseline cardiovascular disease and cancer.

Abbreviations: CI = confidence interval; HR = hazard ratio; MVI = multivitamin; NR = not reported; PHS-II = Physician's Health Study II; REACT = Roche European American Cataract Trial; RR = relative risk; SU.VI.MAX = Supplementation in VItamins and Mineral Antioxidants Study; y = years.

### Harms

Four good-quality RCTs (n=28,607)50-52,55 and one good-quality prospective cohort study (n=72,337)53 reported on harms (Appendix E Tables 1 and 2). NHS examined the associations between hip fractures and multivitamin intake in postmenopausal women (aiming to examine the influence of the vitamin A component specifically).53 This cohort study found a statistically significant increase in hip fractures among current multivitamin users compared with nonusers (RR, 1.32 [95% CI, 1.04 to 1.67]) and a nonsignificant increased risk among former users (RR, 1.25 [95% CI, 0.97 to 1.61]).

REACT reported that hypercarotenemia (yellowing of the skin) developed in six patients (presumably in the treatment arm).51 Other side effects and intercurrent illnesses did not differ by treatment group and were not considered serious; no further details were provided. SU.VI.MAX reported minor side effects in less than 10 participants taking the multivitamin supplement, and none withdrew due to these side effects (no further details were provided).55 PHS-II found no significant effects on gastrointestinal tract symptoms (e.g., peptic ulcer, constipation, gastritis, and nausea), fatigue, drowsiness, skin discoloration, or migraine.50 Multivitamin supplement users were more likely to have rashes than the placebo group (p=0.03). PHS-II found mixed results for bleeding events, with significantly more cases of hematuria (p=0.02) and epistaxis (p=0.01) in the multivitamin group than the placebo group, but no difference in the number of participants who easily bruised or other bleeding events (p=0.77).50

The study by Graat and colleagues found no difference between groups in the incidence or severity of acute respiratory tract infection or in total illness duration, number of symptoms, number of fevers, number of participants with restriction to activity, or episode-related medication use, suggesting neither harm nor benefit for respiratory-related outcomes in older adults with multivitamin supplementation.52

## KQ 3 What Is the Efficacy of Supplementation With Single Nutrients or Functionally Related Nutrient Pairs on Health Outcomes in the General Adult Population?

## KQ 4 What Is Known About the Safety of Single Nutrient Use in the General Adult Population?

The third and fourth KQs for this review concerned single supplements and various pairs of supplements. We found no trials that reported incidence of CVD or cancer or all-cause mortality for four B vitamins (1, 2, 6, or 12), iron, zinc, magnesium, niacin, calcium/magnesium, folic acid/vitamin B_12_, or folic acid/vitamin B_6_. Overall, the available studies for beta-carotene; vitamins A, C, D, and E; selenium; folic acid; calcium; and some combinations found no evidence for a benefit of the supplement on CVD, cancer, or all-cause mortality. Instead, two studies using beta-carotene for those at high risk for lung cancer (i.e., smokers and/or asbestos-exposed workers) found that participants in the supplement groups were at a significantly higher risk of developing or dying from lung cancer.59,60

### Beta-Carotene

#### Summary of Results

Six good-quality RCTs (n=112,820) examined beta-carotene supplementation alone or in combination with another study supplement, such as vitamin E or A (Table 13).59-64 No effects were seen on CVD outcomes or on overall cancer incidence, but there was an increase in lung cancer incidence and mortality and in all-cause mortality in two trials of participants at high risk for lung cancer at baseline (i.e., smokers and/or asbestos-exposed workers).59 One of these trials, which examined beta-carotene in combination with vitamin A, terminated early due to the increase in risk.60 Yellowing of the skin was the most frequently reported adverse effect with beta-carotene supplementation.

Table 13 Beta-Carotene Evidence Summary

Study Quality | Study design Followup | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
ATBC59,66,69-73,76-78,87,88,155-157 Good | 2×2 factorial RCT 16 years (max) | Beta-carotene 20 mg qd (alone or in combination with vitamin E 50 mg qd) 6.1 years (mean) (range, 5 to 8 years) | 29,133 | 57 | 0 | NR | Any: ↔ Lung: ↑^*^ CRC: ↔^†^ Prostate Breast: NA Other: ↔ | ↑ | ↓ | Baseline population at high risk for lung cancer (all smokers)
PHS-I61,65,68,158 Good | 2×2 factorial RCT 12 years | Beta-carotene 50 mg qod (alone or in combination with aspirin) 12 years (mean) | 22,071 | NR | 0 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: NA Other: ↑^‡^ | ↔ | ↔
WHS62 Good | 2×2×2 RCT 4.1 years | Beta-carotene 50 mg qod (alone or in combination with vitamin E 600 IU qod and/or aspirin) 2.1 years (median) (range, 0 to 2.72 years) | 39,876 | 55 | 100 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: NA Breast: ↔ Other: ↔ | ↔ | ↔
SCPS63,75,159 Good | RCT 8.2 years | Beta-carotene 50 mg qd 5 years | 1,805 | 63 | 31 | NA | NA | ↔ | ↔
NSCPS64,160 Good | 2×2 factorial RCT 4.5 years | Beta-carotene 30 mg qd (alone or in combination with topical sunscreen) 4.5 years | 1,621 | 49 | 56 | NA | NA | ↔ | ↔
CARET60,67,74, 161-164 Good | RCT 11 years | Beta-carotene 30 mg qd and vitamin A 25,000 IU qd NR | 18,314 | 58 | 34 | NA | Any: ↔ Lung: ↑^*^ CRC: ↔ Prostate: ↔ Breast: ↔ Other: ↔ | ↑ | ↔ | Baseline population at high risk for lung cancer (smokers or asbestos-exposed workers)

* Including deaths due to lung cancer.

† Late negative effect after 14 years of followup.

‡ Increased risk for thyroid and bladder cancer after 12 years of followup.

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; bid = twice daily; CARET = Carotene and Retinol Efficacy Trial; CRC = colorectal cancer; CVD = cardiovascular disease; MI = myocardial infarction; NA = not applicable; NR = not reported; NSCPS = Nambour Skin Cancer Prevention Study; PHS-I = Physician's Health Study I; qd = once daily; qod = every other day; RCT = randomized, controlled trial; SCPS = Skin Cancer Prevention Study; WHS = Women's Health Study; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified six RCTs (n=112,820) examining the efficacy and safety of beta-carotene supplementation (Appendix E Tables 1 and 2): the Alpha-Tocopherol Beta-Carotene Cancer Prevention (ATBC) trial,59 PHS-I,61 the Women's Health Study (WHS),62 SCPS,63 the Nambour Skin Cancer Prevention Study (NSCPS),64 and the Carotene and Retinol Efficacy Trial (CARET).60 While two RCTs included for efficacy (SCPS and NSCPS) reported incidence of skin cancer, these trials were designed to examine the effectiveness of beta-carotene supplementation on the secondary prevention of skin cancer (i.e., prevention of new skin cancer in patients with BCC and/or SCC); thus, we only considered their mortality outcomes.63,64

The six RCTs examining the efficacy and/or safety of beta-carotene were all double-blind, placebo-controlled trials. Three were 2×2 factorial-designed trials randomizing participants to beta-carotene or another intervention (daily sunscreen,64 vitamin E,59 or aspirin61) and one was a 2×2×2 factorial-designed trial randomizing participants to beta-carotene, vitamin E, or aspirin.62 One study randomized participants to a combination supplement of beta-carotene and vitamin A.60 The doses ranged from 30 mg daily60,64 to 50 mg daily59,63 or every other day;61,62 all other supplements (e.g., vitamins E, A) were within the DRI as set forth by the Food and Nutrition Board (Appendix A Table 1).

Two trials included only men, one included only women, and the others included both sexes. The ATBC trial was conducted among 29,133 male smokers (mean age, 57.2 years) without a history of cancer. Because almost 25 percent of the baseline population had a history of CVD, the only outcomes considered in this report were cancer, all-cause mortality, and harms.59 PHS-I was conducted among 22,071 healthy male physicians (mean age, 53 years) in the United States.61 WHS was conducted among 39,876 healthy female health professionals age 45 years or older.62 NSCPS was conducted among residents of the city of Nambour in southeast Queensland, Australia who took part in a skin cancer prevention study (56% female; mean age, 48.7 years), of which nearly 27 percent had a history of skin cancer (i.e., BCC or SCC).64 SCPS randomized 1,805 individuals (31% female; mean age, 63 years) at high risk for NMSC (i.e., a previous history of BCC or SCC) and was designed to examine whether a beta-carotene supplement would decrease the time to first reoccurrence and the number of new skin cancer cases.63 CARET aimed to prevent lung cancer among two separate high-risk groups (n=18,314), asbestos-exposed workers and heavy smokers.60 The asbestos-exposed group included all men, while the heavy smokers included men and women (34.3% of entire study population was female).

We rated five of the six trials as good quality.59-62,64 Among the good-quality studies, adherence was relatively high in four trials, with 70 to 93 percent of participants taking at least 80 percent of the assigned supplements. Even though three trials were discontinued early, two due to null findings (PHS-I and WHS)61,62 and the other due to the increased risk of developing lung cancer and mortality among its participants (CARET),60 they were rated good quality. SCPS was rated fair because it did not report randomization or blinding procedures.63

#### CVD

Two RCTs (n=61,947) examined incidence of nonfatal MI and nonfatal stroke as primary outcomes and found no statistically significant effect from beta-carotene supplementation (Table 14).61,62 Although there were more CVD-related deaths in the beta-carotene intervention groups in four of the five trials, none of the between-group differences were statistically significant.60-64 There were also no significant effects on the incidence of diabetes mellitus among participants taking beta-carotene in PHS-I (RR, 0.99 [95% CI, 0.86 to 1.14])65 or the ATBC trial (RR, 0.99 [95% CI, 0.85 to 1.15]; data not shown).66

Table 14 Cardiovascular Disease Incidence and Mortality Among Beta-Carotene Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR^*^ | 95% CI | P-value
Any CVD^§^ | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 967/11,036 (8.8) | 972/11,035 (8.8) | 1.0 | 0.91 to 1.09 | 0.09
Any CVD^§^ | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 116/19,937 (0.6) | 102/19,939 (0.5) | 1.14 | 0.87 to 1.49 | 0.34
MI incidence | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 468/11,036 (4.2) | 489/11,035 (4.4) | 0.96 | 0.84 to 1.09 | 0.50
MI incidence | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 42/19,937 (0.2) | 50/19,939 (0.3) | 0.84 | 0.56 to 1.27 | 0.41
Stroke incidence | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 367/11,036 (3.3) | 382/11,035 (3.5) | 0.96 | 0.83 to 1.11 | 0.60
Stroke incidence | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 61/19,937 (0.3) | 43/19,939 (0.2) | 1.42 | 0.96 to 2.10 | 0.08
Any CVD death | NSCPS64 | Beta-carotene vs. placebo | 4.5 | 6/820 (0.7) | 12/801 (1.5) | NR | NR | NR
Any CVD death | SCPS75 | Beta-carotene vs. placebo | 8.2 | 68/913 (7.4) | 59/892 (6.6) | 1.16 | 0.82 to 1.64 | 0.41
Any CVD death | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 14/19,937 (0.1) | 12/19,939 (0.1) | 1.17 | 0.54 to 2.53 | 0.69
Any CVD death | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 338/11,036 (3.1) | 313/11,035 (2.8) | 1.09 | 0.93 to 1.27 | 0.28
Any CVD death | CARET67,74 | Beta-carotene + vitamin A vs. placebo | 4 | NR | NR | 1.26 | 0.99 to 1.61 | NR
Any CVD death | CARET67,74 | Beta-carotene + vitamin A vs. placebo | 6^†^ | 354/8,744 (4) | 319/8,396 (3.8) | 1.02 | 0.88 to 1.19 | NR

* Adjusted for age (PHS-I, WHS), random assignment (PHS-I, WHS), and/or multivariate (SCPS: age, sex, study center, previous skin cancer, age at diagnosis, skin type, smoking status, baseline plasma levels); unadjusted (CARET).

† Not cumulative, total number of deaths during 6-year posttrial period only (i.e., does not include deaths during supplementation phase).

§ Includes nonfatal strokes, nonfatal MI, and cardiovascular-related death.

Abbreviations: CARET = Carotene and Retinol Efficacy Trial; CI = confidence interval; CVD = cardiovascular disease; MI = myocardial infarction; NSCPS = Nambour Skin Cancer Prevention Study; NR = not reported; PHS-I = Physician's Health Study I; RR = relative risk; SCPS = Skin Cancer Prevention Study; WHS = Women's Health Study; y = years.

#### Cancer

Four RCTs (n=109,394) reported cancer incidence with mixed results, largely due to populations studied (Table 15).59-62 Any cancer (except NMSC) was the primary outcome for two trials (PHS-I and WHS), while the incidence of lung cancer was the primary outcome for the other two trials (CARET and ATBC). PHS-I and WHS found no effect of beta-carotene on the incidence of any cancer, including lung cancer, in average-risk adults (Figure 3),61,62 while CARET and the ATBC trial found statistically significant increased incidence of lung cancer with beta-carotene supplementation after 4 and 6.1 years followup, respectively.59,60 Participants in the ATBC trial and CARET were at high risk for lung cancer at baseline, as study investigators specifically recruited current heavy smokers or asbestos-exposed workers. The risk of developing lung cancer was mitigated with longer followup and was no longer statistically significant in either CARET or the ATBC trial after 10 and 11 years, respectively.

Table 15 Cancer Incidence and Mortality Among Beta-Carotene Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR | 95% CI | P-value
Any cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12 | 1,273/11,036 (11.5) | 1,293/11,035 (11.7) | 0.98 | 0.91 to 1.06 | 0.65
Any cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12.9 | 1,314/11,036 (11.9) | 1,353/11,035 (12.3) | 1.0 | 0.9 to 1.0 | 0.41
Any cancer incidence | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 378/19,937 (1.9) | 369/19,939 (1.9) | 1.03 | 0.89 to 7.18 | 0.73
Lung cancer incidence | ATBC^*,59,73^ | Beta-carotene vs. no beta-carotene | 6.1 | 474/14,560 (3.3) | 402/14,573 (2.8) | 1.18 | 1.03 to 1.36 | 0.01
Lung cancer incidence | ATBC^*,59,73^ | Beta-carotene vs. no beta-carotene | 8 | 481/14,560 (3.3) | 414/14,573 (2.8) | 1.17 | 1.02 to 1.33 | NR
Lung cancer incidence | ATBC^*,59,73^ | Beta-carotene vs. no beta-carotene | 11^¶^ | 266/12,559 (2.1) | 232/12,724 (1.8) | 1.17 | 0.98 to 1.39 | NR
Lung cancer incidence | ATBC^*,59,73^ | Beta-carotene vs. no beta-carotene | 14^¶^ | 262/11,276 (2.3) | 277/11,562 (2.4) | 0.97 | 0.82 to 1.15 | NR
Lung cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12 | 82/11,036 (0.7) | 88/11,035 (0.8) | 0.93 | 0.69 to 1.26 | NR
Lung cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12.9 | 85/11,036 (0.8) | 93/11,035 (0.8) | 0.90 | 0.7 to 1.2 | 0.54
Lung cancer incidence | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 31/19,937 (0.2) | 21/19,939 (0.1) | NR | NR | NR
Lung cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 4 | 229/9,420 (2.4) | 159/8,894 (1.8) | 1.28 | 1.04 to 1.57 | 0.02
Lung cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 6 | 376/8,744 (4.3) | 311/8,396 (3.7) | 1.12 | 0.97 to 1.31 | 0.13
Breast cancer incidence | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 169/19,937 (0.8) | 168/19,939 (0.8) | NR | NR | NR
Breast cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 4 | 59/3,208 (1.8) | 65/3,081 (2.1) | 0.78 | 0.55 to 1.12 | 0.18
Prostate cancer incidence | ATBC^*,59,73,157^ | Beta-carotene vs. no beta-carotene | 6.1^†^ | 136/14,560 (0.9) | 110/14,573 (0.8) | 1.23 | 0.96 to 1.59 | 0.088
Prostate cancer incidence | ATBC^*,59,73,157^ | Beta-carotene vs. no beta-carotene | 8 | 138/14,560 (0.9) | 110/14,573 (0.8) | 1.26 | 0.98 to 1.62 | NR
Prostate cancer incidence | ATBC^*,59,73,157^ | Beta-carotene vs. no beta-carotene | 11^¶^ | 149/12,614 (1.2) | 128/12,776 (1) | 1.18 | 0.94 to 1.50 | NR
Prostate cancer incidence | ATBC^*,59,73,157^ | Beta-carotene vs. no beta-carotene | 14^¶^ | 193/11,237 (1.7) | 202/11,533 (1.8) | 0.98 | 0.81 to 1.20 | NR
Prostate cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12 | 520/11,036 (4.7) | 527/11,035 (4.8) | 0.98 | 0.88 to 1.11 | NR
Prostate cancer incidence | PHS-I61,68 | Beta-carotene vs. no beta-carotene | 12.9 | 551/11,036 (5) | 566/11,035 (5.1) | 1.0 | 0.9 to 1.1 | 0.62
Prostate cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 4 | 161/6,212 (2.6) | 139/5,813 (2.4) | 1.01 | 0.80 to 1.27 | 0.95
Prostate cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 11 | 462/6,197 (7.4) | 428/5,803 (7.4) | NR | NR | NSD
Colorectal cancer incidence | ATBC^*,59,73,77^ | Beta-carotene vs. no beta-carotene | 6.1^†^ | 69/14,560 (0.5) | 66/14,573 (0.5) | 1.05 | 0.75 to 1.47 | NR
Colorectal cancer incidence | ATBC^*,59,73,77^ | Beta-carotene vs. no beta-carotene | 8 | 69/14,560 (0.5) | 66/14,573 (0.5) | 1.05 | 0.75 to 1.47 | NR
Colorectal cancer incidence | ATBC^*,59,73,77^ | Beta-carotene vs. no beta-carotene | 11^¶^ | 47/12,670 (0.4) | 45/12,819 (0.4) | 1.06 | 0.70 to 1.60 | NR
Colorectal cancer incidence | ATBC^*,59,73,77^ | Beta-carotene vs. no beta-carotene | 14^¶^ | 73/11,373 (0.6) | 40/11,631 (0.3) | 1.88 | 1.28 to 2.76 | NR
Colorectal cancer incidence | PHS-I61,68,‡ | Beta-carotene vs. no beta-carotene | 12 | 167/11,036 (1.5) | 174/11,035 (1.6) | 0.96 | 0.78 to 1.18 | NR
Colorectal cancer incidence | PHS-I61,68,‡ | Beta-carotene vs. no beta-carotene | 12.9 | 170/11,036 (1.5) | 176/11,035 (1.6) | 0.97 | 0.78 to 1.19 | NR
Colorectal cancer incidence | WHS62,‡ | Beta-carotene vs. no beta-carotene | 4.1 | 34/19,937 (0.2) | 34/19,939 (0.2) | 1.0 | 0.8 to 1.2 | NR
Colorectal cancer incidence | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 4 | 56/9,420 (0.6) | 50/8,894 (0.6) | 1.02 | 0.70 to 1.50 | 0.91
Any cancer death | NSCPS64 | Beta-carotene vs. placebo | 4.5 | 3/820 (0.4) | 7/801 (0.9) | NR | NR | NR
Any cancer death | SCPS75 | Beta-carotene vs. placebo | 8.2 | 38/913 (4.2) | 44/892 (4.9) | 0.83 | 0.54 to 1.29 | 0.41
Any cancer death | WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 31/19,937 (0.2) | 28/19,939 (0.1) | 1.11 | 0.67 to 1.85 | 0.69
Any cancer death | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 386/11,036 (3.5) | 380/11,035 (3.4) | 1.02 | 0.89 to 1.18 | 0.76
Lung cancer death | SCPS75 | Beta-carotene vs. placebo | 8.2 | 13/913 (1.4) | 17/892 (1.9) | NR | NR | NR
Lung cancer death | PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 63/11,036 (0.6) | 62/11,035 (0.6) | NR | NR | NR
Lung cancer death | ATBC59,73 | Beta-carotene vs. no beta-carotene | 6.1 | 302/14,560 (2.1) | 262/14,573 (1.8) | NR | NR | 0.08
Lung cancer death | ATBC59,73 | Beta-carotene vs. no beta-carotene | 12.1 | 1,524/5,298^§^ (28.8) | | NR | NR | NR
Lung cancer death | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 4 | NR | NR | 1.17 | 1.03 to 1.33 | 0.02
Lung cancer death | CARET60,67,74 | Beta-carotene + vitamin A vs. placebo | 6^§^ | 1,225/8,744 (14) | 1,047/8,396 (12.5) | 1.08 | 0.99 to 1.17 | 0.07
Prostate cancer death | ATBC76 | Beta-carotene vs. no beta-carotene | 6 | 33/14,560 (0.2) | 29/14,573 (0.2) | 1.15 | 0.70 to 1.89 | NR

* Overall 6-year posttrial followup: lung cancer RR, 1.06 (95% CI, 0.94 to 1.20); prostate cancer RR, 1.06 (95% CI, 0.91 to 1.23); colorectal cancer RR, 1.44 (95% CI, 1.09 to 1.90).

† Subsequent ATBC publications after the initial publication59 reclassified cancer cases: three additional prostate cancer cases were identified and seven were reclassified as nonmalignant; colorectal cancer cases excluded six participants with carcinoids and squamous cell carcinoma of the anal canal, an additional eight colorectal cancer cases were reclassified based on pathology.

‡ Combined colon and rectal cancer cases.

§ Total number of deaths during 6-year posttrial period only (excludes supplementation period).

¶ Not cumulative; incidence during posttrial followup periods only (11 years: May 1993 to April 1996; 14 years: May 1996 to April 1999).

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; CI = confidence interval; NR = not reported; NSCPS = Nambour Skin Cancer Prevention Study; PHS-I = Physician's Health Study I; RR = relative risk; SCPS = Skin Cancer Prevention Study; WHS = Women's Health Study; y = years.

Beta-carotene supplementation had no statistically significant effect on breast,62,67 prostate,59,67,68 pancreatic,62,68,69 stomach,59,62,68 gastric,70 urothelial,71 renal cell,71 uterine,62 ovarian,62 cervical,62 brain,62,68 head/neck,67 oral/pharyngeal,72 esophageal,72 laryngeal,72, kidney,73 lymphoma,62,67,68 leukemia,62,67,68 and melanoma cancer incidence rates (data not shown).62,68 PHS-I found a statistically significant increased risk for thyroid (p=0.003) and bladder (p=0.04) cancer among those randomized to receive beta-carotene after 12.9 years of followup (data not shown).68 The ATBC trial, CARET, and WHS found no statistically significant difference in bladder cancer (data not shown).59,62,67 WHS found no difference in the incidence of thyroid cancer among women after 4.1 years (data not shown).62 The ATBC trial found a late effect on the overall incidence of colorectal cancer only during the 6 years posttrial (RR, 1.44 [95% CI, 1.09 to 1.90]),73 while no other trials found a statistically significant effect on this cancer.62,67,68 The variation of these site-specific cancer results most likely reflects the post hoc nature of the testing, variation in baseline risk among populations recruited for different study aims, and lower power for relatively rare cancers due to small sample sizes.

Cancer mortality was reported in six RCTs (n=112,820) with mixed results.59-64 Four trials found no statistically significant difference with beta-carotene supplementation in the number of cancer-related deaths.61-64 As with incidence, however, there were more lung cancer deaths among those randomized to receive beta-carotene than those who were not, especially among the two trials of high-risk participants (ATBC and CARET).59,60 These harmful results, along with consideration of the negative effects on lung cancer prevention identified in the ATBC trial, led to the early discontinuation of CARET. Even with further followup in CARET, those who had been taking the beta-carotene in combination with vitamin A supplement were at an increased risk of lung cancer mortality (RR, 1.20 [95% CI, 1.01 to 1.43]).74 In the two high-risk subgroups of this trial, only smokers had an increased risk of dying from lung cancer at 6 years of followup (RR, 1.21 [95% CI, 1.00 to 1.47]), not the asbestos-exposed workers (RR, 1.16 [95% CI, 0.77 to 1.75]). PHS-I, WHS, and SCPS did not show any statistically significant effects with beta-carotene supplementation on lung cancer mortality, probably due to the participants' low risk at baseline.61,62,75

Beta-carotene supplementation had no statistically significant effects on prostate,76 colorectal,77 pancreatic,69 urothelial,71 renal cell,71 oral/pharyngeal,72 esophageal,72 and laryngeal cancer deaths (data not shown).72

#### All-Cause Mortality

All-cause mortality was reported in six RCTs (n=112,820) (Table 16).59-64 Four RCTs showed no significant effect on all-cause mortality among participants taking beta-carotene (Figure 4). The only statistically significant increases were among the two trials (ATBC and CARET) that specifically recruited participants at risk for lung cancer (i.e., heavy smokers and/or asbestos-exposed workers).59,60

Table 16 All-Cause Mortality Among Beta-Carotene Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR | 95% CI | P-value
SCPS63,75 | Beta-carotene vs. placebo | 5 | 79/913 (8.7) | 72/892 (8.1) | 1.08 | 0.98 to 1.19 | NR
SCPS63,75 | Beta-carotene vs. placebo | 8.2 | 146/913 (16) | 139/892 (15.6) | 1.03 | 0.82 to 1.30 | 0.80
NSCPS64 | Beta-carotene vs. placebo | 4.5 | 11/820 (1.3) | 21/801 (2.6) | NR | NR | NR
PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 979/11,036 (8.9) | 968/11,035 (8.8) | 1.02 | 0.93 to 1.11 | 0.68
WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 59/19,937 (0.3) | 55/19,939 (0.3) | 1.07 | 0.74 to 1.56 | 0.70
ATBC^†,59,73^ | Beta-carotene vs. no beta-carotene | 6.1 | 1,851/14,560 (12.7) | 1,719/14,573 (11.8) | 1.08 | 1.01 to 1.16 | 0.02
ATBC^†,59,73^ | Beta-carotene vs. no beta-carotene | 8 | 1,851/14,560 (12.7) | 1,719/14,573 (11.8) | 1.08 | 1.01 to 1.15 | NR
ATBC^†,59,73^ | Beta-carotene vs. no beta-carotene | 11^§^ | 1,278/12,709 (10.1) | 1,164/12,914 (9) | 1.11 | 1.03 to 1.21 | NR
ATBC^†,59,73^ | Beta-carotene vs. no beta-carotene | 14^§^ | 1,455/11,431 (12.7) | 1,401/11,690 (12) | 1.07 | 0.99 to 1.15 | NR
ATBC^†,59,73^ | Beta-carotene vs. no beta-carotene | 16^§^ | 971/9,976 (9.7) | 992/10,289 (9.6) | 1.01 | 0.92 to 1.10 | NR
CARET60,74 | Beta-carotene + vitamin A vs. placebo | 4 | NR | NR | 1.17^*^ | 1.03 to 1.33 | 0.02
CARET60,74 | Beta-carotene + vitamin A vs. placebo | 6^‡^ | 1,225/8,744 (14) | 1,047/8,396 (12.5) | 1.08^*^ | 0.99 to 1.17 | 0.07

* Unadjusted.

† Overall 6-year posttrial mortality rate was also statistically significant (RR, 1.07 [95% CI, 1.02 to 1.12]).73

‡ Total number of deaths during 6-year posttrial period only (excludes supplementation period).

§ Not cumulative; incidence during posttrial followup periods only (11 years: May 1993 to April 1996; 14 years: May 1996 to April 1999; 16 years: May 1999 to April 2001).

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; CI = confidence interval; NR = not reported; NSCPS = Nambour Skin Cancer Prevention Study; PHS-I = Physician's Health Study I; RR = relative risk; SCPS = Skin Cancer Prevention Study; WHS = Women's Health Study; y = years.

#### Harms

Few details on adverse events were reported in six beta-carotene trials (n=112,820).59-64 PHS-I reported no major side effects associated with the intervention during the 12 years of followup.61 In NSCPS, 8 percent of participants withdrew from the study due to symptoms attributed to the study tablets or were unwilling to take the tablets (65 in the intervention group vs. 64 in the control group).64 Four percent of participants in SCPS stopped taking the study capsules due to capsule-related symptoms (49 in the intervention group vs. 31 in the control group) within the first 2 years of the study.63

Yellowing of the skin was the most commonly reported adverse event (Table 17). There were no statistically significant differences in the number of minor gastrointestinal symptoms (e.g., belching) or other minor side effects (e.g., headaches) in PHS-I,61 WHS,62 and CARET.60

Table 17 Yellowing of the Skin Among Beta-Carotene Studies

Study | Comparison | Mean followup (y) | # of events among participants receiving beta-carotene (%) | # of events among participants not receiving beta-carotene (%)
ATBC59 | Beta-carotene vs. no beta-carotene | 6.1 | 4,950/14,560 (34) | 1,020/14,573 (7)
PHS-I61 | Beta-carotene vs. no beta-carotene | 12 | 1,745/11,036 (15.8) | 1,535/11,035 (13.9)
WHS62 | Beta-carotene vs. no beta-carotene | 4.1 | 2,131/19,937 (10.7) | 1,944/19,939 (9.7)
SCPS63,* | Beta-carotene vs. placebo | 5 | 12/913 (1.3) | 0/892 (0)
CARET^†,60^ | Beta-carotene + vitamin A vs. placebo | 4 | 28/9,420 (0.3) | NR

* Reported among participants who stopped taking the study capsules due to capsule-related symptoms.

† Skin yellowing of grade 3 or higher (grade 1 representing normal or no symptoms; grades 4–5 representing severe symptoms).

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; NR = not reported; PHS-I = Physician's Health Study I; SCPS = Skin Cancer Prevention Study; WHS = Women's Health Study; y = years.

In a post hoc analysis, the ATBC trial also examined the effect of beta-carotene supplementation on the incidence of hospital-treated pneumonia in male smokers and found no overall effect (RR, 0.98 [95% CI, 0.85 to 1.11]).78 Men who started smoking at an older age (>20 years) and were assigned to receive beta-carotene were at a higher risk for pneumonia than those who started smoking at a younger age (p=0.004).

### Vitamin E

#### Summary of Results

Six fair- to good-quality trials of vitamin E supplementation, alone or in combination with another supplement, met our inclusion criteria (n=120,335).52,59,79-82 This is the largest set of studies on any supplement included in this report. No beneficial effects were seen on CVD, cancer, or all-cause mortality (Table 18).

Table 18 Vitamin E Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
ATBC59,66,69-73,76-78,87,88,155-157 Good | 2×2 factorial RCT 16 years | Vitamin E 50 mg qd (alone or in combination with beta-carotene 20 mg qd) 6.1 years (mean) (range, 5 to 8 years) | 29,133 | 57 | 0 | NA | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↓^‡^ Breast: NA Other: ↔ | ↔ | ↔
ASAP79 Fair | 2×2 factorial RCT 3 years | Vitamin E 91 mg bid (alone or in combination with vitamin C 250 mg bid) 3 years | 520 | 60 | 51 | NA | NA | ↔ | ↔
PHS-II80,83,154 Good | 2×2×2×2 factorial RCT 8 years | Vitamin E 400 IU qd (alone or in combination with beta-carotene, vitamin C, and/or MVI) 8 years (median) | 14,641 | 64 | 0 | Any: ↔ Stroke: ↔ MI: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: NA Other: ↔ | ↔ | ↔ | Hemorrhagic stroke (↑)
WHS81,165 Good | 2×2×2 factorial RCT 10.1 years | Vitamin E 600 IU qod (alone or in combination with beta-carotene 50 mg qod or aspirin) 10.1 years (mean) (range, 8.2 to 10.9 years) | 39,876 | 55 | 100 | Any: ↔ Stroke: ↔ MI: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: NA Breast: ↔ Other: ↔ | ↔ | ↔ | CVD death (↓); mixed bleeding adverse effects: hematuria (↔), gastrointestinal bleeding (↔), bruising (↔), and epistaxis (↑)
Graat 2002^52^ Good | 2×2 factorial RCT 1.3 years | Vitamin E 200 mg qd (alone or in combination with MVI) 1.3 years | 652 | 73 | 50 | NA | NA | NA | ↔ | Respiratory infections (↔)
SELECT82,86,143, 166-171 Good | RCT 12 years | Vitamin E 400 IU qd (alone or in combination with selenium 200 mcg qd) 5.46 years (median) (range, 7 to 12 years) | 35,533 | 63 | 0 | Any: ↔ Stroke: NR MI: NR | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↑^†^ Breast: NA Other: ↔ | ↔ | ↔

† Increasing risk with longer followup (i.e., >5 years) in vitamin E alone intervention group.

‡ Including prostate cancer deaths.

Abbreviations: ASAP = Antioxidant Supplementations in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; bid = twice daily; CRC = colorectal cancer; CVD = cardiovascular disease; MI = myocardial infarction; MVI = multivitamin; NA = not applicable; NR = not reported; PHS-II = Physician's Health Study II; qd = once daily; qod = every other day; RCT = randomized, controlled trial; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study; y = year.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified six RCTs evaluating vitamin E (n=120,335) (Appendix E Tables 1 and 2).52,59,79-82 The trial by Graat and colleagues, described previously in the multivitamin section, included a separate vitamin E arm.52 This study was a small, good-quality RCT that randomized 652 men and women older than age 60 years to a multivitamin or vitamin E (200 mg daily) in a 2×2 factorial design. The main outcome for this trial was acute respiratory infection. The other five trials were ATBC (described previously),59 PHS-II (described previously),80 the Selenium and Vitamin E Cancer Prevention Trial (SELECT),82 WHS (described previously),81 and the Antioxidant Supplementations in Atherosclerosis Prevention (ASAP) study.79

The RCTs were all double-blind, placebo-controlled trials. We rated them as good quality, except for ASAP, which we rated fair because it did not specify blinding, randomization, or outcome assessment methods. Two of the trials had 2×2 factorial designs, randomizing participants to vitamin E (200 mg daily52 or 30 mg daily59), another study supplement (a multivitamin52 or beta-carotene), both, or placebo.59 WHS had a 2×2×2 factorial design with three active intervention groups: vitamin E (600 IU every other day), beta-carotene (50 mg every other day), and aspirin (50 mg every other day).81 PHS-II had a 2×2×2×2 factorial design with four active intervention groups: vitamin E (400 IU), vitamin C (500 mg), a multivitamin, or beta-carotene.83 SELECT randomized participants to selenium (200 mcg), vitamin E (400 IU), both, or placebo.82 ASAP also had a 2×2 factorial design that randomized 520 individuals with hypercholesterolemia (51% female) to vitamin E (91 mg), vitamin C (50 mg), both, or placebo in order to prevent atherosclerosis.

Three trials included only men and one included only women. The ATBC trial was conducted in 29,133 male smokers (mean age, 57.2 years) to prevent lung cancer;59 PHS-II was conducted in 14,641 male physicians (mean age, 64.3 years) to prevent CVD and cancer. SELECT was conducted in 35,533 men older than age 50 years to prevent prostate cancer.82 Only one trial (WHS) was conducted in women: 39,876 female health professionals (mean age, 55 years) to prevent CVD and cancer.81

#### CVD

Three trials (n=90,050) reported cardiovascular incidence and mortality (Figure 2).80-82 As reported in a secondary analysis, SELECT found no evidence of any impact on any “serious” cardiovascular event (including death) from vitamin E supplementation alone or combined with selenium (Table 19).82 PHS-II and WHS reported incidence rates for nonfatal MI and nonfatal stroke (both primary outcomes in addition to CVD death) and showed no statistically significant effect.80,81 In PHS-II, there was an excess number of hemorrhagic strokes observed among those assigned to vitamin E compared with those not assigned to vitamin E (39 vs. 23 events; p=0.036).80 The other two studies (WHS and SELECT) found no statistically significant differences in the number of hemorrhagic strokes with vitamin E supplementation (data not shown).81,82 This difference among these trials likely reflects the small number of these specific events and the post hoc analysis.

Table 19 Cardiovascular Disease Incidence and Mortality Among Vitamin E Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any CVD incidence | SELECT82,‡ | Vitamin E vs. placebo | 5 | 1,034/8,737 (11.8) | 1,050/8,696 (12.1) | 0.98^*^ | 0.88 to 1.09^†^ | NR
Any CVD incidence | SELECT82,‡ | Vitamin E + selenium vs. placebo | 5 | 1,041/8,703 (12) | 1,050/8,696 (12.1) | 0.99^*^ | 0.89 to 1.10^†^ | NR
Any CVD incidence | PHS-II80,¶ | Vitamin E vs. no vitamin E | 8 | 620/7,315 (8.5) | 625/7,326 (8.5) | 1.01^*^ | 0.90 to 1.13 | 0.86
Any CVD incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 482/19,937 (2.4) | 517/19,939 (2.6) | 0.93 | 0.82 to 1.05 | 0.26
CHF incidence | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 289/7,315 (4) | 294/7,326 (4) | 1.02^*^ | 0.87 to 1.20 | 0.80
CHF incidence | WHS165 | Vitamin E vs. no vitamin E | 10.1 | 106/19,913 (0.5) | 114/19,902 (0.6) | 0.93^*^ | 0.71 to 1.21 | 0.59
MI incidence | PHS-II80,‖ | Vitamin E vs. no vitamin E | 8 | 240/7,315 (3.3) | 271/7,326 (3.7) | 0.90^*^ | 0.75 to 1.07 | 0.22
MI incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 196/19,937 (1) | 195/19,939 (1) | 1.01 | 0.82 to 1.23 | 0.96
Stroke incidence | PHS-II80,‖,‡ | Vitamin E vs. no vitamin E | 8 | 327/7,315 (4.5) | 227/7,326 (3.1) | 1.07^*^ | 0.89 to 1.29 | 0.45
Stroke incidence | WHS81,‡ | Vitamin E vs. no vitamin E | 10.1 | 241/19,937 (1.2) | 246/19,939 (1.2) | 0.98 | 0.82 to 1.17 | 0.82
Stroke incidence | SELECT82,§ | Vitamin E vs. placebo | 5 | 70/8,737 (0.8) | 92/8,696 (1) | NR | NR | NR
Stroke incidence | SELECT82,§ | Vitamin E + selenium vs. placebo | 5 | 99/8,703 (1.1) | 92/8,696 (1) | NR | NR | NR
Angina incidence | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 689/7,315 (9.4) | 736/7,326 (10) | 0.94^*^ | 0.85 to 1.05 | NR
Any CVD death | SELECT82,‡ | Vitamin E vs. placebo | 5 | 119/8,737 (1.4) | 142/8,696 (1.6) | 0.84^*^ | 0.61 to 1.15^†^ | NR
Any CVD death | SELECT82,‡ | Vitamin E + selenium vs. placebo | 5 | 117/8,703 (1.3) | 142/8,696 (1.6) | 0.82^*^ | 0.60 to 1.13^†^ | NR
Any CVD death | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 258/7,315 (3.5) | 251/7,326 (3.4) | 1.07^*^ | 0.90 to 1.28 | 0.43
Any CVD death | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 106/19,937 (0.5) | 140/19,939 (0.7) | 0.76 | 0.59 to 0.98 | 0.03
Fatal MI | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 22/7,315 (0.3) | 30/7,326 (0.4) | 0.75^*^ | 0.43 to 1.31 | NR
Fatal MI | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 12/19,937 (0.1) | 14/19,939 (1) | 0.86 | 0.40 to 1.85 | 0.70
Fatal stroke | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 45/7,315 (0.6) | 56/7,326 (0.8) | 0.86^*^ | 0.58 to 1.27 | NR
Fatal stroke | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 21/19,937 (0.1) | 24/19,939 (0.1) | 0.88 | 0.49 to 1.57 | 0.66

* HR; SELECT was adjusted for age, sex, and smoking status at baseline.

† 99% CI.

‡ Includes CVD-related deaths; nonfatal strokes and other nonfatal CVD events also reported.

§ Number of events and the HR for hemorrhagic, ischemic, and unspecified stroke type also reported.

‖ Nonfatal and fatal events.

¶ Includes nonfatal MI, nonfatal stroke, and CVD deaths.

Abbreviations: CHF = coronary heart failure; CI = confidence interval; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; NR = not reported; PHS-II = Physician's Health Study II; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study; y = years.

A subgroup analysis in WHS found that older women (age 65 years and older) who had received vitamin E supplementation had a significant reduction in major cardiovascular events (p=0.009), while younger women (ages 45 to 54 years and 55 to 64 years) had no effect.81

The same three trials also reported on CVD mortality (n=90,050) (Table 19).80-82 The CVD mortality rate in WHS was lower in the intervention group (RR, 0.76 [95% CI, 0.59 to 0.98]), but the overall 10-year mortality rate was very low (0.6%).81 The mortality rates for fatal MI and strokes did not reach statistical significance. The between-group differences in CVD mortality rates in the two all-male trials (PHS-II and SELECT) did not reach statistical significance.80,82 The benefit seen in WHS could well reflect a chance finding given the small number of events, or the biological effects of vitamin E may be different in women than men. This speculation is supported by different effects of aspirin for primary CVD prevention in men and women.84,85

#### Cancer

Any and/or site-specific cancer incidence was reported as a primary outcome in four RCTs (n=119,183) (Table 20).59,81-83 The ATBC study reported significantly less prostate cancer incidence among participants randomized to vitamin E than those who were not randomized to vitamin E at 6.1 and 8 years followup (p=0.002).73,76 These differences did not persist at longer followup times (i.e., after 11 and 14 years),73 although no information is known about supplement use after the trial ended. SELECT and PHS-II also reported prostate cancer incidence and neither found any evidence of an effect at the end of their trials.82,83 In an extended followup of SELECT participants, however, there were significantly more prostate cancer cases in the vitamin E only group than in placebo (p=0.008).82 SELECT and PHS-II each had more than twice the number of prostate cancer cases than did ATBC, which may explain the different results. Certainly the extended SELECT results call into question any conclusion that vitamin E might protect against prostate cancer.

Table 20 Cancer Incidence and Mortality Among Vitamin E Studies

Outcome | Study | Comparison | Mean followup ( y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
All cancer sites incidence | SELECT82 | Vitamin E vs. placebo | 5 | 856/8,737 (9.8) | 824/8,696 (9.5) | 1.03^*^ | 0.91 to 1.17^‡^ | NR
All cancer sites incidence | SELECT82 | Vitamin E vs. placebo | 12 | 1,190/8,737 (13.6) | 1,108/8,696 (12.7) | 1.07^*^ | 0.96 to 1.19^‡^ | 0.13
All cancer sites incidence | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 846/8,703 (9.7) | 824/8,696 (9.5) | 1.02^*^ | 0.90 to 1.16^†^ | NR
All cancer sites incidence | SELECT82 | Vitamin E + selenium vs. placebo | 12 | 1,149/8,703 (13.2) | 1,108/8,696 (12.7) | 1.02^*^ | 0.92 to 1.14^†^ | 0.60
All cancer sites incidence | PHS-II83 | Vitamin E vs. no vitamin E | 8 | 984/7,315 (13) | 959/7,326 (13) | 1.04^*^ | 0.95 to 1.13 | 0.41
All cancer sites incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 1,437/19,937 (7.2) | 1,428/19,939 (7.2) | 1.01 | 0.94 to 1.08 | 0.87
Lung cancer incidence | SELECT82 | Vitamin E vs. placebo | 5 | 67/8,737 (0.8) | 67/8,696 (0.8) | 1.00^*^ | 0.64 to 1.55^‡^ | NR
Lung cancer incidence | SELECT82 | Vitamin E vs. placebo | 12 | 104/8,737 (1.2) | 92/8,696 (1.1) | 1.11^*^ | 0.76 to 1.61^‡^ | 0.49
Lung cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 78/8,703 (0.9) | 67/8,696 (0.8) | 1.16^*^ | 0.76 to 1.78^†^ | NR
Lung cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 12 | 104/8,703 (1.2) | 92/8,696 (1.1) | 1.11^*^ | 0.76 to 1.62^†^ | 0.48
Lung cancer incidence | ATBC59,73,¶ | Vitamin E vs. no vitamin E | 6.1 | 433/14,564 (3) | 443/14,569 (3) | 1.02 | NR | 0.8
Lung cancer incidence | ATBC59,73,¶ | Vitamin E vs. no vitamin E | 8 | 444/14,564 (3) | 451/14,569 (3.1) | 0.99 | 0.87 to 1.12 | NR
Lung cancer incidence | ATBC59,73,¶ | Vitamin E vs. no vitamin E | 11^†^ | 238/12,627 (1.9) | 260/12,656 (2.1) | 0.92 | 0.77 to 1.09 | NR
Lung cancer incidence | ATBC59,73,¶ | Vitamin E vs. no vitamin E | 14^†^ | 287/11,431 (2.5) | 252/11,405 (2.2) | 1.14 | 0.96 to 1.35 | NR
Lung cancer incidence | PHS-II83 | Vitamin E vs. no vitamin E | 8 | 48/7,315 (0.7) | 55/7,326 (0.8) | 0.89^*^ | 0.60 to 1.31 | 0.55
Lung cancer incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 107/19,937 (0.5) | 98/19,939 (0.5) | 1.09 | 0.83 to 1.44 | 0.52
Prostate cancer incidence | SELECT82 | Vitamin E vs. placebo | 5 | 473/8,737 (5.4) | 416/8,696 (4.8) | 1.13^*^ | 0.99 to 1.29 | 0.06
Prostate cancer incidence | SELECT82 | Vitamin E vs. placebo | 12 | 620/8,737 (7.1) | 529/8,696 (6.1) | 1.17^*^ | 1.04 to 1.36^‡^ | 0.008
Prostate cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 437/8,703 (5) | 416/8,696 (4.8) | 1.05^*^ | 0.91 to 1.20^†^ | 0.52
Prostate cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 12 | 555/8,703 (6.4) | 529/8,696 (6.1) | 1.05^*^ | 0.89 to 1.22^†^ | 0.46
Prostate cancer incidence | ATBC59,73,76,¶ | Vitamin E vs. no vitamin E | 6.1^‖^ | 99/14,564 (0.7) | 147/14,569 (1) | 0.68 | 0.44 to 0.94 | 0.002
Prostate cancer incidence | ATBC59,73,76,¶ | Vitamin E vs. no vitamin E | 8 | 99/14,564 (0.7) | 149/14,569 (1) | 0.66 | 0.52 to 0.86 | NR
Prostate cancer incidence | ATBC59,73,76,¶ | Vitamin E vs. no vitamin E | 11^†^ | 130/12,696 (1) | 147/12,694 (1.2) | 0.89 | 0.70 to 1.12 | NR
Prostate cancer incidence | ATBC59,73,76,¶ | Vitamin E vs. no vitamin E | 14^†^ | 185/11,410 (1.6) | 210/11,360 (1.8) | 0.88 | 0.72 to 1.07 | NR
Prostate cancer incidence | PHS-II83 | Vitamin E vs. no vitamin E | 8 | 493/7,315 (6.7) | 515/7,326 (7) | 0.97^*^ | 0.85 to 1.09 | 0.58
Breast cancer incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 616/19,937 (3.1) | 614/19,939 (3.1) | 1.00 | 0.90 to 1.12 | 0.95
Colorectal cancer incidence | SELECT82 | Vitamin E vs. placebo | 5 | 66/8,737 (0.8) | 60/8,696 (0.7) | 1.09^*^ | 0.69 to 1.73^‡^ | NR
Colorectal cancer incidence | SELECT82 | Vitamin E vs. placebo | 12 | 85/8,737 (1.0) | 75/8,696 (0.9) | 1.09^*^ | 0.72 to 1.64^‡^ | 0.60
Colorectal cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 77/8,703 (0.9) | 60/8,696 (0.7) | 1.28^*^ | 0.82 to 2.00^†^ | NR
Colorectal cancer incidence | SELECT82 | Vitamin E + selenium vs. placebo | 12 | 93/8,703 (1.1) | 75/8,696 (0.9) | 1.21^*^ | 0.81 to 1.81^†^ | 0.22
Colorectal cancer incidence | ATBC59,73,77 | Vitamin E vs. no vitamin E | 6.1^‖^ | 59/14,564 (0.4) | 76/14,569 (0.5) | 0.78 | 0.55 to 1.09 | NSD
Colorectal cancer incidence | ATBC59,73,77 | Vitamin E vs. no vitamin E | 8 | 59/14,564 (0.4) | 76/14,569 (0.5 | 0.78 | 0.55 to 1.09 | NR
Colorectal cancer incidence | ATBC59,73,77 | Vitamin E vs. no vitamin E | 11^†^ | 50/12,733 (0.4) | 42/12,756 (0.3) | 1.19 | 0.79 to 1.80 | NR
Colorectal cancer incidence | ATBC59,73,77 | Vitamin E vs. no vitamin E | 14^†^ | 57/11,521 (0.5) | 56/11,483 (0.5) | 1.02 | 0.70 to 1.47 | NR
Colorectal cancer incidence | PHS-II83 | Vitamin E vs. no vitamin E | 8 | 75/7,315 (1) | 87/7,326 (1.2) | 0.88^*^ | 0.64 to 1.19 | 0.40
Colorectal cancer incidence | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 129/19,937 (0.6) | 140/19,939 (0.7) | NR | NR | NR
Any cancer death | SELECT | Vitamin E vs. placebo | 5 | 106/8,737 (1.2) | 125/8,696 (1.4) | 0.84^*^ | 0.60 to 1.18^‡^ | NR
Any cancer death | SELECT | Vitamin E + selenium vs. placebo | 5 | 117/8,703 (1.3) | 125/8,696 (1.4) | 0.93^*^ | 0.67 to 1.30^†^ | NR
Any cancer death | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 273/7,315 (3.7) | 250/7,326 (3.4) | 1.13^*^ | 0.95 to 1.34 | 0.16
Any cancer death | WHS81 | Vitamin E vs. no vitamin E | 10.1 | 308/19,937 (1.5) | 275/19,939 (1.4) | 1.12 | 0.95 to 1.32 | 0.17
Lung cancer death | SELECT82 | Vitamin E vs. placebo | 5 | 38/8,737 (0.4) | 41/8,696 (0.5) | 0.92^*^ | 0.52 to 1.65^‡^ | NR
Lung cancer death | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 39/8,703 (0.4) | 41/8,696 (0.5) | 0.95^*^ | 0.53 to 1.69^†^ | NR
Lung cancer death | ATBC59,73 | Vitamin E vs. no vitamin E | 6.1 | 285/14,564 (2) | 279/14,569 (1.9) | NR | NR | NR
Lung cancer death | ATBC59,73 | Vitamin E vs. no vitamin E | 12.1 | 942/5,298^§^ (17.8) | | NR | NR | NR
Lung cancer death | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 44/7,315 (0.6) | 43/7,326 (0.6) | 1.05^*^ | 0.69 to 1.60 | NR
Prostate cancer death | SELECT82 | Vitamin E vs. placebo | 5 | 0/8,737 (0) | 0/8,696 (0) | NA | NA | NA
Prostate cancer death | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 0/8,703 (0) | 0/8,696 (0) | NA | NA | NR
Prostate cancer death | ATBC76 | Vitamin E vs. no vitamin E | 6.1 | 23/14,564 (0.2) | 39/14,569 (0.3) | 0.59 | 0.35 to 0.99 | NR
Prostate cancer death | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 37/7,315 (0.5) | 39/7,326 (0.5) | 1.01^*^ | 0.64 to 1.58 | NR
Colorectal cancer death | SELECT82 | Vitamin E vs. placebo | 5 | 13/8,737 (0.1) | 10/8,696 (0.1) | 1.30^*^ | 0.44 to 3.83^‡^ | NR
Colorectal cancer death | SELECT82 | Vitamin E + selenium vs. placebo | 5 | 15/8,703 (0.2) | 10/8,696 (0.1) | 1.49^*^ | 0.52 to 4.28^†^ | NR
Colorectal cancer death | ATBC77 | Vitamin E vs. no vitamin E | 6.1 | 22/14,564 (0.2) | 14/14,569 (0.1) | 0.92 | 0.51 to 1.64 | NR
Colorectal cancer death | PHS-II80 | Vitamin E vs. no vitamin E | 8 | 21/7,315 (0.3) | 32/7,326 (0.4) | 0.68^*^ | 0.39 to 1.18 | NR

* HR reported.

† Not cumulative; incidence during posttrial followup periods only (11 years: May 1993 to April 1996; 14 years: May 1996 to April 1999).

‡ 99% CI.

‖ Subsequent ATBC publications after the initial publication59 reclassified cancer cases: three additional prostate cancer cases were identified and seven were reclassified as nonmalignant; colorectal cancer cases excluded six participants with carcinoids and squamous cell carcinoma of the anal canal, an additional eight colorectal cancer cases were reclassified based on pathology.

¶ Overall 6-year posttrial followup: lung cancer RR, 1.03 (95% CI, 0.91 to 1.16); prostate cancer RR, 0.88 (95% CI, 0.76 to 1.03).

§ Total number of deaths during 6-year posttrial period.

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; HR = hazard ratio; NR = not reported; PHS-II = Physician's Health Study II; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study; y = years.

None of the trials reported a statistically significant effect of vitamin E on the incidence of all cancers combined (Figure 3)81-83 or of other site-specific cancers, including lung,59,73,81-83 breast,81 colorectal,59,73,77,81-83 gastric,70 stomach,59,73,81 kidney,73 pancreatic,69,83 urothelial,71 renal cell,71 oral/pharyngeal,72 esophageal,72 laryngeal,72 epithelial,83 leukemia,83 bladder,59,83,86 lymphoma,83 and melanoma (data not shown).83

Three RCTs (n=90,050) reported overall cancer mortality and none of the between-group differences were significant (Table 20).81-83 Vitamin E supplementation showed no statistically significant effects on lung,59,73,82,83 colorectal,77,82,83 pancreatic,69,83 bladder,83 urothelial,71 esophageal,72 and laryngeal cancer72 mortality rates or mortality rates from lymphoma,83 leukemia,83 and melanoma83 (data not shown). In ATBC, there were significantly fewer male smokers dying from prostate cancer with vitamin E supplementation than those without vitamin E supplementation (RR, 0.59 [95% CI, 0.35 to 0.99]).76 PHS-II, however, found no significant differences in prostate cancer mortality rates (RR, 1.01 [95% CI, 0.64 to 1.58])83 and SELECT reported no prostate cancer deaths in any of the vitamin E arms (only one death in the control group).82 Again, the number of prostate cancer deaths is small in all three trials, so chance may be playing a role. Also, in the ATBC trial, half of the men taking vitamin E were also taking beta-carotene and may have died from lung cancer before any prostate cancer became evident.

#### All-Cause Mortality

Five trials reported all-cause mortality data (n=119,703) (Figure 4).59,79-82 The small ASAP study reported four deaths among those receiving vitamin E (either alone or combined with vitamin C) and one in the placebo group.79 The other four trials found no difference in all-cause mortality between intervention and control groups (Table 21).59,80-82

Table 21 All-Cause Mortality Among Vitamin E Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR or HR | 95% CI | P-value
SELECT82 | Vitamin E vs. placebo | 5 | 358/8,737 (4.1) | 382/8,696 (4.4) | 0.93^*^ | 0.77 to 1.13^‡^ | NR
SELECT82 | Vitamin E vs. placebo | 12 | 571/8,737 (6.5) | 564/8,696 (6.5) | 1.01^*^ | 0.86 to 1.17^‡^ | 0.91
SELECT82 | Vitamin E + selenium vs. placebo | 5 | 359/8,703 (4.2) | 382/8,696 (4.4) | 0.94^*^ | 0.77 to 1.13^‡^ | NR
SELECT82 | Vitamin E + selenium vs. placebo | 12 | 542/8,703 (6.2) | 564/8,696 (6.5) | 0.96^*^ | 0.82 to 1.12^‡^ | 0.47
ASAP79 | Vitamin E vs. placebo | 3 | 3/130 (2.3) | 1/130 (0.8) | NR | NR | NR
ASAP79 | Vitamin E + vitamin C vs. placebo | 3 | 1/130 (0.8) | 1/130 (0.8) | NR | NR | NR
ATBC59,73 | Vitamin E vs. no vitamin E | 6.1 | 1,800/14,564 (12.4) | 1,760/14,569 (12.1) | 1.02 | 0.95 to 1.09 | 0.6
ATBC59,73 | Vitamin E vs. no vitamin E | 8 | 1,800/14,564 (12.4) | 1,770/14,569 (12.1) | 1.02 | 0.95 to 1.09 | NR
ATBC59,73 | Vitamin E vs. no vitamin E | 11^†^ | 1,193/12,764 (9.3) | 1,249/12,799 (9.8) | 0.96 | 0.89 to 1.04 | NR
ATBC59,73 | Vitamin E vs. no vitamin E | 14^†^ | 1,460/11,571 (12.6) | 1,396/11,550 (12.1) | 1.05 | 0.97 to 1.13 | NR
ATBC59,73 | Vitamin E vs. no vitamin E | 16^†^ | 980/10,111 (9.7) | 983/10,154 (9.7) | 1.00 | 0.92 to 1.10 | NR
PHS-II80 | Vitamin E vs. no vitamin E | 8 | 841/7,315 (11.5) | 820/7,326 (11.2) | 1.08^*^ | 0.98 to 1.19 | 0.13
WHS81 | Vitamin E vs. no vitamin E | 10.1 | 636/19,937 (3.2) | 615/19,939 (3.1) | 1.04 | 0.93 to 1.16 | 0.53

* HR.

† Not cumulative; incidence during posttrial followup periods only (11 years: May 1993 to April 1996; 14 years: May 1996 to April 1999; 16 years: May 1999 to April 2001).

‡ 99% CI.

Abbreviations: ASAP = Antioxidant Supplementations in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; HR = hazard ratio; NR = not reported; PHS-II = Physician's Health Study II; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study; y = years.

#### Harms

All six vitamin E trials reported on harms (n=120,355).52,59,79-82 PHS-II reported no differences between groups in observed adverse events, including bleeding, gastrointestinal symptoms, fatigue, drowsiness, skin discoloration, rashes, and migraines.80 As discussed previously, there was a significantly greater risk of hemorrhagic stroke among participants receiving vitamin E supplementation in PHS-II (p=0.036), but this was not seen in the other two trials (WHS and SELECT). WHS reported a slight increase in epistaxis (RR, 1.06 [95% CI, 1.01 to 1.11]), but no other differences between groups in hematuria, gastrointestinal bleeding, or bruising.81

The study by Graat and colleagues evaluated the effect of vitamin E on respiratory tract infections in elderly men and women.52 While supplementation had no significant effect on the incidence of infection (RR, 1.12 [95% CI, 0.88 to 1.25]), the severity of infection was worse among those who did not receive vitamin E, with longer duration, more symptoms, more fever, and more restricted activity. The ATBC trial also examined the effect of vitamin E supplementation on the incidence of hospital-treated pneumonia in male smokers and found no overall effect (RR, 1.00 [95% CI, 0.88 to 1.14]).78 Men who started smoking at an older age (>20 years) and were assigned to receive vitamin E were at a lower risk for pneumonia than those who started smoking at a younger age (p=0.0007).78 Among those who started smoking before age 21 years, those who weighed less than 60 kg or greater than 100 kg, had a greater dietary vitamin C intake (i.e., above the median), and had a lack of exercise were associated with a statistically significant increased risk for pneumonia.87,88

SELECT reported no statistically significant increase in alopecia, dermatitis, halitosis, nail changes, or fatigue among participants randomized to vitamin E alone or in combination with selenium when compared with placebo.82 In the ASAP study, there was a similar number of dropouts due to severe and nonsevere adverse events between groups; no further details were provided.79

### Selenium

#### Summary of Results

Two fair- to good-quality RCTs (n=36,845) examining selenium, either alone or in combination with another study supplement, found no effect on CVD or all-cause mortality.82,89 The results were mixed for cancer prevention (Table 22). The Nutritional Prevention of Cancer Study (NPC) found a statistically significant decreased risk of cancer incidence and cancer-related mortality among participants randomized to selenium (p<0.05), with decreased risk of prostate and colorectal cancer specifically (p<0.05 for each).89 The benefits decreased over time. SELECT, however, found no effect of selenium supplementation, either alone or in combination with vitamin E, on incidence of any site-specific cancer or all cancer combined, or on cancer mortality.82 The differences in results between trials may be attributed to a number of factors, including the lower quality rating of NPC and the different inclusion criteria. In addition, NPC's participants were drawn from a geographical area known to have low soil selenium levels (eastern United States). In a post hoc analysis, the benefits were seen only in men in the lowest tertile of selenium levels at baseline, so any benefits may reflect treatment of selenium deficiency. No apparent harms from selenium supplementation were identified in three trials (n=37,346).

Table 22 Selenium Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
NPC89,90,92-95,172,173 Fair | RCT 7.6 years | Selenium 200 mcg qd 4.5 years (mean) | 1,312 | 63 | 25 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↓ Lung: ↔ CRC: ↓ Prostate: ↓ Breast: ↔ Other: ↔ | ↔ | ↔ | Cancer-related mortality (↓)
SELECT82,86,143,166-171 Good | RCT 5 years with extended followup | Selenium 200 mcg qd (alone or in combination with vitamin E 400 IU qd) 5.46 years (median) (range, 7 to 12 years) | 35,533 | 63 | 0 | Any: ↔ MI: NR Stroke: NR | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: NA Other: ↔ | ↔ | ↔ | Mixed dermatological harms among arms: selenium alone (↑) and selenium + vitamin E (↔)
U.K. PRECISE91 Fair | RCT 0.5 years | Selenium 100, 200, or 300 mcg qd 0.5 years | 501 | 67 | 47 | NA | NA | NA | ↔ | No serious harms reported; stomach and abdominal discomfort (↔)

Abbreviations: CRC = colorectal cancer; CVD = cardiovascular disease; max = maximum; MI = myocardial infarction; NA = not applicable; NPC = Nutritional Prevention of Cancer; NR = not reported; qd = once daily; RCT = randomized, controlled trial; SELECT = Selenium and Vitamin E Cancer Prevention Trial; U.K. PRECISE = U.K. Prevention of Cancer by Intervention with Selenium; y = year.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

Three trials (n=37,346) of selenium supplementation met our inclusion criteria: NPC,89,90 SELECT, and the U.K. Prevention of Cancer by Intervention with Selenium (U.K. PRECISE) (Appendix E Tables 1 and 2).82 The fair-quality NPC recruited 1,312 men (75%) and women (25%) with a history of at least two SCCs or BCCs of the skin who lived in areas of the United States known to have low levels of environmental selenium.89 The mean age of participants was 63 years and 28 percent were current smokers. The main hypothesis of the study, that selenium supplementation at nutritional levels (200 mcg daily) would reduce the risk of BCC and SCC, was not supported by the results. Below we report secondary cancer and cardiovascular outcomes and safety data. We rated NPC as having fair quality due to its lack of blinding and randomization methods. As discussed previously, the good-quality SELECT randomized 35,533 men older than age 50 years to selenium (200 mcg/d), vitamin E (400 IU/d), both, or placebo to prevent prostate cancer.82 The good-quality U.K. PRECISE pilot trial randomized 501 older adults (mean age, 67.5 years; 47.4% female) to 100, 200, or 300 mcg of selenium or placebo.91 Only harms from selenium supplementation have been reported.

#### CVD

Neither SELECT nor NPC (as reported in secondary analyses) found any evidence of effects with selenium supplementation, either alone or in combination with vitamin E, on CVD (n=36,845) (Table 23, Figure 2).82,89 NPC specifically examined the incidence of coronary heart disease (i.e., fatal and nonfatal MI, coronary bypass graft surgery, or percutaneous transluminal coronary angioplasty), cerebrovascular events (i.e., stroke or carotid endarterectomy), or CVD-related death among participants without a history of CVD (n=1,004), while SELECT collected self-reported “serious” cardiac events. There were no statistically significant differences in the incidence of diabetes mellitus between either of the selenium and placebo arms at either followup time points in SELECT (data not shown).82

Table 23 Cardiovascular Disease Incidence and Mortality Among Selenium Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any CVD incidence | NPC173 | Selenium vs. placebo | 7.6 | 103/504 (20.4) | 96/500 (19.2) | 1.03^*^ | 0.78 to 1.37 | 0.81
Any CVD incidence | SELECT82,† | Selenium vs. placebo | 5 | 1,080/8,752 (12.3) | 1,050/8,696 (12.1) | 1.02^‖^ | 0.92 to 1.13^‡^ | NR
Any CVD incidence | SELECT82,† | Selenium + vitamin E vs. placebo | 5 | 1,041/8,703 (12) | 1,050/8,696 (12.1) | 0.99 | 0.89 to 1.10^‡^ | NR
Coronary heart disease incidence | NPC173 | Selenium vs. placebo | 7.6 | 63/504 (12.5) | 59/500 (11.8) | 1.04^*^ | 0.73 to 1.49 | 0.81
Cerebrovascular events incidence | NPC173 | Selenium vs. placebo | 7.6 | 40/504 (7.9) | 37/500 (7.4) | 1.02^*^ | 0.65 to 1.59 | 0.94
MI incidence | NPC173 | Selenium vs. placebo | 7.6 | 41/504 (8.1) | 43/500 (8.6) | 0.94^*^ | 0.61 to 1.44 | 0.77
Stroke incidence | NPC173 | Selenium vs. placebo | 7.6 | 35/504 (6.9) | 32/500 (6.4) | 1.02^*^ | 0.63 to 1.65 | 0.92
Stroke incidence | SELECT82,¶ | Selenium vs. placebo | 5 | 73/8,752 (0.8) | 92/8,696 (1) | NR | NR | NR
Stroke incidence | SELECT82,¶ | Vitamin E + selenium vs. placebo | 5 | 99/8,703 (1.1) | 92/8,696 (1) | NR | NR | NR
Any CVD death | NPC89,92,173 | Selenium vs. placebo | 6 | 47/653 (7.2) | 46//659 (7) | 1.00 | 0.66 to 1.55 | 0.96
Any CVD death | NPC89,92,173 | | 7.6 | 40/504 (7.9) | 31/500 (6.2) | 1.22^*^ | 0.76 to 1.95 | 0.41
Any CVD death | SELECT § | Selenium vs. placebo | 5 | 129/8,752 (1.5) | 142/8,696 (1.6) | 0.91^‖^ | 0.66 to 1.24 | NR
Any CVD death | SELECT § | Selenium + vitamin E vs. placebo | 5 | 117/8,703 (1.3) | 142/8,696 (1.6) | 0.82^*^ | 0.60 to 1.13^†^ | NR
Fatal MI | NPC173 | Selenium vs. placebo | 7.6 | 9/504 (1.8) | 8/500 (1.6) | 1.05^*^ | 0.42 to 2.80 | 0.88

* HR; adjusted for age, sex, and smoking status at baseline.

† Includes CVD-related deaths; nonfatal strokes and other nonfatal CVD events also reported.

‡ 99% CI reported.

§ Fatal hemorrhagic stroke and other fatal CVD events (not specified) also reported.

‖ HR; analyses did not incorporate adjustments for baseline covariates.

¶ Number of events and the HR for hemorrhagic, ischemic, and unspecified stroke type also reported.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; NR = not reported; NPC = Nutritional Prevention of Cancer; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; y = years.

#### Cancer

The two selenium trials had mixed cancer outcomes (n=36,845) (Table 24, Figure 3).82,89 SELECT found no evidence of effects on the incidence of prostate, lung, colorectal, or any cancer overall at or beyond 5 years of followup with selenium supplementation.82 In contrast, NPC reported significant 6-year decreases in any cancer,89,92 prostate,89,92,93 lung,89,92 and colorectal cancer.89,92 However, with longer-term followup through the end of the blinded trial (over 7 years), the differences in lung90,94 and colorectal cancer90 became statistically nonsignificant. The risk for any cancer90 and prostate cancer90,95 lessened but remained significant. The differences in results between trials may be attributed to a number of factors, including the lower quality rating for NPC and the different inclusion criteria (history of NMSC for NPC, normal prostate examination and prostate-specific antigen level in SELECT). Perhaps most importantly, NPC's participants were drawn from a geographical area known to have low soil selenium levels (eastern United States) and the benefits were seen only in men in the lowest tertile of baseline selenium, so if the apparent benefits are true, they may reflect treatment of selenium deficiency. NPC was a much smaller trial (n=1,312) than SELECT (n=35,533) and pooled analyses show no difference in cancer outcomes (RR for any cancer incidence, 0.91 [95% CI, 0.70 to 1.18]) (Figure 3).

Table 24 Cancer Incidence and Mortality Among Selenium Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR^‡^ or HR | 95% CI | P-value
Any cancer incidence | NPC89,90,92 | Selenium vs. placebo | 6 | 77/653 (11.8) | 119/659 (18.1) | 0.63 | 0.47 to 0.85 | 0.001
Any cancer incidence | NPC89,90,92 | Selenium vs. placebo | 7.4 | 105/621 (16.9) | 137/629 (21.8) | 0.75 | 0.58 to 0.98 | 0.03
Any cancer incidence | SELECT82 | Selenium vs. placebo | 5 | 837/8,752 (9.6) | 824/8,696 (9.5) | 1.01^*^ | 0.89 to 1.15^†^ | NR
Any cancer incidence | SELECT82 | Selenium vs. placebo | 12 | 1,132/8,752 (12.9) | 1,108/8,696 (12.7) | 1.02^*^ | 0.92 to 1.14^†^ | 0.59
Any cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 846/8,703 (9.7) | 824/8,696 (9.5) | 1.02^*^ | 0.90 to 1.16^†^ | NR
Any cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 12 | 1,149/8,703 (13.2) | 1,108/8,696 (12.7) | 1.02^*^ | 0.92 to 1.14^†^ | 0.60
Prostate cancer incidence | NPC89,90,92,93,95 | Selenium vs. placebo | 6 | 13/479 (2.7) | 35/495 (7.1) | 0.37 | 0.18 to 0.71 | 0.002
Prostate cancer incidence | NPC89,90,92,93,95 | Selenium vs. placebo | 7.4 | 22/457 (4.8) | 42/470 (8.9) | 0.51 | 0.29 to 0.88 | 0.009
Prostate cancer incidence | SELECT82 | Selenium vs. placebo | 5 | 432/8,752 (4.9) | 416/8,696 (4.8) | 1.04^*^ | 0.90 to 1.18^†^ | 0.62
Prostate cancer incidence | SELECT82 | Selenium vs. placebo | 12 | 575/8,752 (6.6) | 529/8,696 (6.1) | 1.09^*^ | 0.93 to 1.27^†^ | 0.18
Prostate cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 437/8,703 (5) | 416/8,696 (4.8) | 1.05^*^ | 0.91 to 1.20^†^ | 0.52
Prostate cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 12 | 555/8,703 (6.4) | 529/8,696 (6.1) | 1.05^*^ | 0.89 to 1.22^†^ | 0.46
Lung cancer incidence | NPC89,90,92,94 | Selenium vs. placebo | 6 | 17/653 (2.6) | 31/659 (4.7) | 0.54 | 0.30 to 0.98 | 0.04
Lung cancer incidence | NPC89,90,92,94 | Selenium vs. placebo | 7.4 | 25/621 (4) | 35/629 (5.6) | 0.70 | 0.40 to 1.21 | 0.18
Lung cancer incidence | SELECT82 | Selenium vs. placebo | 5 | 75/8,752 (0.9) | 67/8,696 (0.8) | 1.12^*^ | 0.73 to 1.72^†^ | NR
Lung cancer incidence | SELECT82 | Selenium vs. placebo | 12 | 94/8,752 (1.1) | 92/8,696 (1.1) | 1.02^*^ | 0.70 to 1.50^†^ | 0.89
Lung cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 78/8,703 (0.9) | 67/8,696 (0.8) | 1.16^*^ | 0.76 to 1.78^†^ | NR
Lung cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 12 | 104/8,703 (1.2) | 92/8,696 (1.1) | 1.11^*^ | 0.76 to 1.62^†^ | 0.48
Colorectal cancer incidence | NPC89,90,92 | Selenium vs. placebo | 6.3 | 8/653 (1.2) | 19/659 (2.9) | 0.42 | 0.18 to 0.95 | 0.03
Colorectal cancer incidence | NPC89,90,92 | Selenium vs. placebo | 7.4 | 9/621 (1.4) | 19/629 (3) | 0.46 | 0.19 to 1.08 | 0.055
Colorectal cancer incidence | SELECT82 | Selenium vs. placebo | 5 | 63/8,752 (0.7) | 60/8,696 (0.7) | 1.05^*^ | 0.66 to 1.67^†^ | NR
Colorectal cancer incidence | SELECT82 | Selenium vs. placebo | 12 | 74/8,752 (0.8) | 75/8,696 (0.9) | 0.96^*^ | 0.63 to 1.46^†^ | 0.79
Colorectal cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 77/8,703 (0.9) | 60/8,696 (0.7) | 1.28^*^ | 0.82 to 2.00^†^ | NR
Colorectal cancer incidence | SELECT82 | Selenium + vitamin E vs. placebo | 12 | 93/8,703 (1.1) | 75/8,696 (0.9) | 1.21^*^ | 0.81 to 1.81^†^ | 0.22
Breast cancer incidence | NPC89,90 | Selenium vs. placebo | 6.3 | 9/653 (1.4) | 3/659 (0.5) | 2.88 | 0.72 to 16.5 | 0.09
Breast cancer incidence | NPC89,90 | Selenium vs. placebo | 7.4 | 11/621 (1.8) | 6/629 (1) | 1.82 | 0.62 to 6.01 | 0.24
Any cancer death | NPC89,90,92 | Selenium vs. placebo | 6.3 | 29/653 (4.4) | 57/659 (8.6) | 0.50 | 0.31 to 0.80 | 0.002
Any cancer death | NPC89,90,92 | Selenium vs. placebo | 7.4 | 40/621 (6.4) | 66/629 (10.5) | 0.59 | 0.39 to 0.89 | 0.008
Any cancer death | SELECT82 | Selenium vs. placebo | 5 | 128/8,752 (1.5) | 125/8,696 (1.4) | 1.02^*^ | 0.74 to 1.41^†^ | NR
Any cancer death | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 117/8,703 (1.3) | 125/8,696 (1.4) | 0.93^*^ | 0.67 to 1.30^†^ | NR
Lung cancer death | NPC89,92 | Selenium vs. placebo | 6 | 12/653 (1.8) | 25/659 (3.8) | 0.47 | 0.22 to 0.98 | 0.03
Lung cancer death | SELECT82 | Selenium vs. placebo | 5 | 45/8,752 (6.9) | 41/8,696 (6.2) | 1.10^*^ | 0.63 to 1.91^†^ | NR
Lung cancer death | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 39/8,703 (0.4) | 41/8,696 (0.5) | 0.95^*^ | 0.53 to 1.69^†^ | NR
Prostate cancer death | SELECT82 | Selenium vs. placebo | 5 | 1/8,752 (0) | 0/8,696 (0) | NA | NA | NA
Prostate cancer death | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 0/8,703 (0) | 0/8,696 (0) | NA | NA | NA
Colorectal cancer death | SELECT82 | Selenium vs. placebo | 5 | 10/8,752 (0.1) | 10/8,696 (0.1) | 1.00^*^ | 0.32 to 3.16^†^ | NR
Colorectal cancer death | SELECT82 | Selenium + vitamin E vs. placebo | 5 | 15/8,703 (0.2) | 10/8,696 (0.1) | 1.49^*^ | 0.52 to 4.28^†^ | NR

* HR; analyses did not incorporate adjustments for baseline covariates.

† 99% CI reported.

‡ Unadjusted.

Abbreviations: CI = confidence interval; HR = hazard ratio; NA = not applicable; NPC = Nutritional Prevention of Cancer; NR = not reported; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; y = years.

NPC found no effect of selenium supplementation on cancers of the head/neck,89,90,92 bladder,89,90,92 esophagus,89,90,92 or breast89,90,92 or on melanoma89,90 or leukemia/lymphoma at any followup times.89,90 NPC also reported a significant decline in cancer mortality for the intervention group at 6 years89,92 and 7.5 years followup.90 Lung cancer deaths were also significantly less in the selenium group than the placebo group after 6 years.89,92 SELECT found no effect of selenium supplementation on any or site-specific cancer mortality.82

#### All-Cause Mortality

There were no differences in mortality in either NPC or SELECT with selenium supplementation (n=36,485) (Table 25, Figure 4).82,89

Table 25 All-Cause Mortality Among Selenium Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR or HR | 95% CI | P-value
NPC89,92,173 | Selenium vs. placebo | 6 | 108/653 (16.5) | 129/659 (19.6) | 0.83^‡^ | 0.63 to 1.08 | 0.14
NPC89,92,173 | Selenium vs. placebo | 7.6 | 110/504 (21.8) | 110/500 (22) | 0.95^§^ | 0.73 to 1.24 | 0.71
SELECT82 | Selenium vs. placebo | 5 | 378/8,752 (4.3) | 382/8,696 (4.4) | 0.99^*^ | 0.82 to 1.19^‖^ | NR
SELECT82 | Selenium vs. placebo | 12 | 551/8,752 (6.3) | 564/8,696 (6.5) | 0.98^*^ | 0.84 to 1.14^‖^ | 0.67
SELECT82 | Selenium + vitamin E vs. placebo | 5 | 359/8,703 (4.2) | 382/8,696 (4.4) | 0.94^*^ | 0.77 to 1.13^‖^ | NR
SELECT82 | Selenium + vitamin E vs. placebo | 12 | 542/8,703 (6.2) | 564/8,696 (6.5) | 0.96^*^ | 0.82 to 1.12^‖^ | 0.47

* HR; analyses did not incorporate adjustments for baseline covariates.

† Noncardiovascular mortality also reported.

‡ Unadjusted.

§ HR; adjusted for age, sex, and smoking status at baseline.

‖ 99% CI reported.

Abbreviations: CI = confidence interval; HR = hazard ratio; NPC = Nutritional Prevention of Cancer; NR = not reported; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial;y = years.

#### Harms

NPC reported no dermatologic signs of selenium toxicity (n=1,312); however, 35 participants withdrew from the study due to adverse effects (e.g., gastrointestinal upset).89 For selenium alone, SELECT found statistically significant increased risks of alopecia (RR, 1.28 [95% CI, 1.01 to 1.62]) and mild dermatitis (RR, 1.17 [95% CI, 1.00 to 1.35]).82 When combined with vitamin E, there were no differences in the incidence of alopecia or mild dermatitis compared with placebo. The U.K. PRECISE trial found no serious harms; stomach or abdominal discomfort were the most frequently reported adverse events and they were equally distributed among arms.91

### Vitamin A

#### Summary of Results

Three fair- to good-quality RCTs (n=20,958) and two cohort studies (n=107,040) examined the efficacy and/or safety of vitamin A supplementation, either alone or in combination with other study supplements (Table 26).53,60,96-98 None of the studies reported CVD incidence. The only RCT (CARET) reporting cancer incidence found a statistically significant increased risk for lung cancer, but not all or other site-specific cancer, among those randomized to receive vitamin A with beta-carotene. This increased risk may be attributed to the beta-carotene supplement, as one other beta-carotene trial also showed statistically significant increased risk for lung cancer among participants at an increased risk at baseline for lung cancer (i.e., smokers) (both trials previously discussed). CARET also found an increased risk of death with the combination supplement, but the only other RCT reporting all-cause mortality with vitamin A supplementation did not (SKICAP-AK). Once again, this may be attributed to the participants' baseline risk. The other included trials found no statistically significant harms in the vitamin A groups. One cohort study among women found a statistically increased risk of harm among past vitamin A users, while the other cohort study did not.

Table 26 Vitamin A Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
SKICAP-AK97,174 Fair | RCT 5 years | Vitamin A 25,000 IU qd 5 years | 2,297 | 63 | 30 | NA | NA | ↔ | ↔
SKICAP-S/B98,174 Fair | RCT 3 years | Vitamin A 25,000 IU qd 3 years | 347 | NR | 28 | NA | NA | NA | ↔
CARET60,67,74,161-164 Good | RCT 11 years | Vitamin A 25,000 IU qd + beta-carotene 30 mg qd NR | 18,314 | 58 | 34 | NA | Any: ↔ Lung: ↑^*^ CRC: ↔ Prostate: ↔ Breast: ↔ Other: ↔ | ↑ | ↔ | Baseline population at high risk for lung cancer (smokers or asbestos-exposed workers)
NHS53 Good | Prospective cohort 18 years | Vitamin A users (dose NR) NR | 72,337 | 58 | 100 | NA | NA | NA | ↑ | Hip fracture among current (↔) and past (↑) vitamin A supplement users
IWHS96 Good | Prospective cohort 9.5 years | Vitamin A users (dose NR) NR | 34,703 | 61 | 100 | NA | NA | NA | ↔ | All fractures (↔) and hip fractures (↔)

* Including lung cancer deaths.

Abbreviations: CARET = Carotene and Retinol Efficacy Trial; CRC = colorectal cancer; CVD = cardiovascular disease; IWHS = Iowa Women's Health Study; max = maximum; NA = not applicable; NHS = Nurses' Health Study; NR = not reported; qd = once daily; RCT = randomized, controlled trial; SKICAP-AK = Skin Cancer Prevention Trial-Actinic Keratoses; SKICAP-S/B = Skin Cancer Prevention Trial-Squamous/Basal Cell Carcinoma; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

As discussed previously, we identified one good-quality RCT (CARET) that examined the efficacy of vitamin A supplementation (25,000 IU daily) in combination with beta-carotene (30 mg daily) to prevent cancer or CVD.60 This study was conducted among 18,314 smokers and asbestos-exposed workers (mean age, 57.5 years). No other vitamin A efficacy trials were identified. We identified two fair-quality RCTs examining the safety of vitamin A supplementation, SKICAP-S/B98 and SKICAP-AK.97

The SKICAP trials were both randomized, double-blind, placebo-controlled trials designed to evaluate the efficacy of vitamin A supplementation to prevent the incidence of NMSC. SKICAP-S/B (n=347) focused on a population at high risk for recurrence of NMSC by requiring a history of four or more pathologically confirmed BCCs or SCCs for inclusion.98 Participants were randomized to receive either 25,000 IU of vitamin A or a placebo once a day for 3 years and were evaluated every 6 months by study staff. A third arm was also included for isotretinion (a vitamin A derivative) (5 to 10 mg). We did not report those outcomes, as isotretinion is not considered a dietary supplement and is used primarily to treat acne. SKICAP-AK (n=2,297) was similar in design to SKICAP-S/B, but focused on a population at moderate risk for developing a recurrence of NMSC.97 Participants were required to have a history of 10 or more pathologically confirmed actinic keratoses (most recent diagnosis within the preceding year) and a pathologically confirmed record of at most one prior SCC or BCC. While both of these trials report skin cancer outcomes, we did not consider those results because neither trial would be considered primary prevention by design; we considered only their all-cause mortality and harms data. We rated both the SKICAP trials as having fair quality due to the lack of randomization methods and allocation concealment.

Two good-quality prospective cohort studies were included for harms: the Iowa Women's Health Study (IWHS)96 and NHS.53 Details of these studies are reported in Appendix E Tables 1 and 2. IWHS (n=34,703) and NHS (n=72,337) were both good-quality large prospective cohorts of postmenopausal women aiming to assess the effectiveness of vitamin supplements in preventing hip fractures.53,96 In addition to hip fractures, IWHS evaluated the impact of vitamin supplements on cancer, diabetes, and hypertension. We only considered those results related to harms, however, due to study design.

#### CVD

As mentioned previously, CARET did not evaluate CVD incidence, and there were no significant differences between groups in the number of CVD-related deaths after 4 years of supplementation and during the 6-year postintervention followup (n=18,314) (Table 14).

#### Cancer

As mentioned previously, there were more incident lung cancer cases and deaths in the combination supplement group than in the placebo group in CARET (n=18,314) after 4 years of followup (p=0.02) (Table 15). With further followup (6 years postintervention), the risk of developing lung cancer was no longer significant (p=0.13), but the related mortality risk was not mitigated. There were no statistically significant differences in the incidence and mortality rates of other site-specific cancers (e.g., prostate, breast, and colorectal).

#### All-Cause Mortality

Two RCTs reported all-cause mortality (n=20,611) (Figure 4). The number of deaths in SKICAP-AK was similar between treatment arms.97 After 5 years of followup, 5.4 percent of the intervention group and 4.5 percent of the control group had died, with a mortality ratio of 1.08 (95% CI, 0.78 to 1.50). In contrast, CARET reported more deaths in the combination supplement group than the placebo group (RR, 1.17 [95% CI, 1.03 to 1.33]) after 4 years, but with longer followup, the difference was no longer significant (p=0.07 after 6 years postintervention) (Table 16). These trials differed in many ways (e.g., size, baseline risk of lung cancer), so this difference in all-cause mortality may simply reflect the clinical heterogeneity between trials, which included the use of beta-carotene supplementation in CARET.

#### Harms

All five included vitamin A studies reported harms (n=127,998).53,60,96-98 Two cohort studies examined associations between hip fractures and vitamin A intake, since high vitamin A intake contributes to osteoporosis by decreasing bone mass.99,100 NHS reported an increase in hip fractures among those who used vitamin A supplements currently (RR, 1.40 [95% CI, 0.99 to 1.99]) or in the past (RR, 1.34 [95% CI, 1.01 to 1.76]) compared with those not taking vitamin A.53 The risk of hip fracture was also increased in a subgroup of women using vitamin A supplements but with low dietary intake of the vitamin (RR, 1.75 [95% CI, 1.09 to 2.80]). This study also found that dietary vitamin A intake increased hip fracture risk.

Similarly, IWHS found an increase in hip fractures that did not quite achieve statistical significance (RR, 1.18 [95% CI, 0.99 to 1.41]) in those taking supplements containing vitamin A.96 During a mean length of followup of 9.5 person-years, there were 6,502 fractures, including 525 hip fractures. Unlike NHS, this study also reported the association of vitamin A supplements with risk of any fracture and found no relationship (RR, 1.00 [95% CI, 0.95 to 1.05]). In both of these studies, investigators relied on self-reported information via questionnaires and were unable to confirm the incidence of a fracture or the site of fracture. Ingesting toxic amounts of vitamin A has adverse skeletal effects in humans and animals, so the results of these two observational studies raise a concern.53

In two trials reporting harms of vitamin A supplements (SKICAP-AK and SKICAP-S/B), no serious adverse events were reported.97,98 In SKICAP-AK, harmful symptoms were rarely reported and were similar in frequency between both study groups through 5 years of followup.97 Symptoms that led to cessation of the medication were also not significantly different between groups. The SKICAP-S/B trial analyzed adverse events by focusing on the number of patients 98 experiencing clinical toxicity (level 2 or greater).98 Similar to SKICAP-AK, occurrences of participants experiencing clinical toxicity were rare, and though instances of toxicity were slightly more common in participants taking vitamin A, the difference was reported to not be significant. CARET also reported no differences in the incidence of adverse effects (e.g., headaches) between those taking the combination supplement and placebo, and only 0.3 percent reported yellowing of skin of grade 3 or higher (Table 17).60 There was also no evidence of systemic toxicity from vitamin A supplementation.

### Vitamin C

#### Summary of Results

Two good- to fair-quality RCTs (n=15,161) examining vitamin C, either alone or in combination with another study supplement, found no effect on preventing CVD, cancer, or all-cause mortality (Table 27).79,80 There were also no differences in harms.

Table 27 Vitamin C Evidence Summary

Study Quality | Study design Followup | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
PHS-II Good80,83,154 | 2×2×2×2 factorial RCT 8 years | Vitamin C 500 mg qd (alone or in combination with vitamin E, beta-carotene, and/or MVI) 8 years (median) | 14,641 | 64 | 0 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: NA Other: ↔ | ↔ | NR
ASAP79 Fair | 2×2 factorial RCT 3 years | Vitamin C 250 mg bid (alone or combined with vitamin E 91 mg bid) 3 years | 520 | 60 | 51 | NA | NA | ↔ | ↔

Abbreviations: ASAP = Antioxidant Supplementations in Atherosclerosis Prevention; bid = twice daily; CRC = colorectal cancer; CVD = cardiovascular disease; MI = myocardial infarction; MVI = multivitamin; NA = not applicable; NR = not reported; PHS-II = Physician's Health Study II; qd = once daily; RCT = randomized, controlled trial; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified one good-quality RCT examining the efficacy of vitamin C in preventing CVD and cancer (PHS-II),80 along with one fair-quality RCT (ASAP) examining the safety of vitamin C supplementation (n=15,161) (Appendix E Tables 1 and 2).79 Both studies have been previously described. PHS-II evaluated the cancer and cardiovascular outcomes for male physicians (age 55 years and older) taking vitamin C (500 mg once a day) against those not taking vitamin C (part of a 2×2×2×2 factorial design).80 ASAP was a double-blind, 2×2 factorial-designed trial focusing on patients with hypercholesterolemia (serum cholesterol of ≥5.0 mmol/L) ages 45 to 69 years.79 The vitamin C arms of the trial included participants taking slow-release vitamin C (250 mg twice a day), either alone (n=130) or in combination with vitamin E (n=130) (91 mg twice a day), over 3 years compared with placebo (n=130).

#### CVD

One good-quality study (PHS-II) (n= 14,641) evaluated the impact of vitamin C supplementation on the primary prevention of major cardiovascular events (nonfatal stroke, nonfatal MI, and CVD death).80 Over an average followup of 8 years, there was no significant difference in the incidence of any major cardiovascular event between those taking vitamin C and those not taking the vitamin (HR, 0.99 [95% CI, 0.89 to 1.11]) (Table 28, Figure 2). Specifically, there were no significant differences in the incidence of MI (p=0.65) or stroke (p=0.21). Death from any CVD event was similar between groups (p=0.86).

Table 28 Cardiovascular Disease Incidence and Mortality Among Vitamin C Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | HR^†^ | 95% CI | P-value
Any CVD incidence^‡^ | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 619/7,329 (8.4) | 626/7,312 (8.6) | 0.99 | 0.89 to 1.11 | 0.91
MI incidence^§^ | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 260/7,329 (3.5) | 251/7,312 (3.4) | 1.04 | 0.87 to 1.24 | 0.65
Stroke incidence^*^ | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 218/7,329 (3) | 246/7,312 (3.4) | 0.89 | 0.89 to 1.07 | 0.21
CHF incidence | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 293/7,329 (4) | 290/7,312 (4) | 1.02 | 0.87 to 1.20 | NR
Angina incidence | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 686/7,329 (9.4) | 739/7,312 (10.1) | 0.92 | 0.97 to 1.18 | NR
Any CVD death | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 256/7,329 (3.5) | 253/7,312 (3.5) | 1.02 | 0.85 to 1.21 | 0.86
Fatal MI | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 30/7,329 (0.4) | 22/7,312 (0.3) | 1.37 | 0.79 to 2.38 | NR
Fatal stroke | PHS-II80 | Vitamin C vs. no vitamin C | 8 | 44/7,329 (0.6) | 57/7,312 (0.8) | 0.77 | 0.52 to 1.14 | NR

* Hemorrhagic and ischemic stroke also reported separately; includes fatal and nonfatal events.

† HRs adjusted for age, study cohort, and randomized assignment.

‡ Includes nonfatal strokes, nonfatal MI, and CVD deaths.

§ Includes fatal and nonfatal events.

Abbreviations: CHF = coronary heart failure; CI = confidence interval; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; NR = not reported; PHS-II = Physician's Health Study II; y = years.

#### Cancer

PHS-II also evaluated the impact of vitamin C supplementation on the primary prevention of cancer (n=14,641) (Table 29, Figure 3).83 There was no significant difference in any or site-specific cancer incidence between those taking vitamin C and those not taking the supplement (HR, 1.01 [95% CI, 0.92 to 1.10]). The incidence and mortality rates of lung, prostate, and colorectal cancer did not differ significantly between the two groups. The number of other cancer (e.g., bladder, epithelial, pancreatic, lymphoma, leukemia, and melanoma) cases and deaths reported were similar between the two groups as well. Death from any type of cancer was similar between groups (p=0.53).

Table 29 Cancer Incidence and Mortality Among Vitamin C Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | HR^*^ | 95% CI | P-value
Any cancer incidence | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 973/7,329 (13.3) | 970/7,312 (13.3) | 1.01 | 0.92 to 1.10 | 0.86
Lung cancer incidence | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 50/7,329 (0.7) | 53/7,312 (0.7) | 0.95 | 0.64 to 1.39 | 0.78
Prostate cancer incidence | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 508/7,329 (6.9) | 500/7,312 (6.8) | 1.02 | 0.90 to 1.15 | 0.80
Colorectal cancer incidence | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 75/7,329 (1) | 87/7,312 (1.2) | 0.86 | 0.63 to 1.17 | 0.35
Any cancer death | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 268/7,329 (3.7) | 255/7,312 (3.5) | 1.06 | 0.89 to 1.25 | 0.53
Lung cancer death | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 39/7,329 (0.5) | 48/7,312 (0.7) | 0.82 | 0.53 to 1.25 | NR
Prostate cancer death | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 45/7,329 (0.6) | 31/7,312 (0.4) | 1.46 | 0.92 to 2.31 | NR
Colorectal cancer death | PHS-II83 | Vitamin C vs. no vitamin C | 8 | 27/7,329 (0.4) | 26/7,312 (0.4) | 1.04 | 0.61 to 1.78 | NR

* HRs adjusted for age, study cohort, and randomized assignment.

Abbreviations: CI = confidence interval; HR = hazard ratio; NR = not reported; PHS-II = Physician's Health Study II; y = years.

#### All-Cause Mortality

Both PHS-II and the ASAP trial (n=15,161) reported all-cause mortality data and found no effect (Table 30, Figure 4). The ASAP trial (n=520) reported one death in each vitamin C arm (alone or in combination with vitamin E) over a 3-year study period.79 The deaths in the intervention group were from subarachnoid hemorrhage or complications of carotid endartectomy, while the single death in the control group was from cardiac dysrhythmia. During PHS-II's 8-year study period (n=14,641), there were 857 deaths in the vitamin C group and 804 deaths in those not taking the vitamin (HR, 1.07 [95% CI, 0.97 to 1.18]).

Table 30 All-Cause Mortality Among Vitamin C Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR | 95% CI | P-value
ASAP79 | Vitamin C vs. placebo | 3 | 1/130 (0.8) | 1/130 (0.8) | NR | NR | NR
ASAP79 | Vitamin C + vitamin E vs. placebo | 3 | 1/130 (0.8) | 1/130 (0.8) | NR | NR | NR
PHS-II80,83 | Vitamin C vs. no vitamin C | 8 | 857/7,329 (11.7) | 804/7,312 (11) | 1.07^*^ | 0.97 to 1.18 | 0.17

* Hazard ratio; adjusted for age, study cohort, and randomized assignment.

Abbreviations: ASAP = Antioxidant Supplementations in Atherosclerosis Prevention; CI = confidence interval; NR = not reported; PHS-II = Physician's Health Study II; RR = relative risk; y = years.

#### Harms

None of the studies identified reported on adverse events from vitamin C supplementation. In ASAP, there were a similar number of dropouts due to severe and nonsevere adverse events between groups; no further details were provided.79

### Folic Acid

#### Summary of Results

One fair-quality RCT (n=1,021) examining folic acid for preventing colorectal adenoma found no effect on MI, strokes, or all-cause mortality, but significantly more noncolorectal cancers in the intervention group than the placebo group (p=0.02) (Table 31).101 The excess in noncolorectal cancer cases was attributed to the higher number of prostate cancers in the intervention group than the placebo group (p=0.02).

Table 31 Folic Acid Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
AFPPS101,102 Fair | 3×2 factorial RCT 10 years | Folic acid 1 mg qd 3 years^*^ | 1,021 | 57 | 36 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↑ Lung: NR CRC: NA Prostate: ↑ Breast: NR Other: NR | ↔ | NR | Paradoxical effect for noncolorectal cancers (↑)

* Subjects invited to continue their random assignment (i.e., folic acid or placebo) for an additional 3 to 5 years after the initial 3-year followup examination; range of followup, 3 to 8 years.

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; CRC = colorectal cancer; CVD = cardiovascular disease; max = maximum; MI = myocardial infarction; NA = not applicable; NR = not reported; qd = once daily; RCT = randomized, controlled trial; y = year.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

Only one study of folic acid supplementation met the inclusion criteria: the Aspirin/Folate Polyp Prevention Study (AFPPS).101,102 This double-blind, placebo-controlled RCT recruited 1,021 adults ages 21 to 80 years with a history of colorectal adenoma and randomized them to folic acid (1 mg daily) or placebo, then separately randomized them to receive aspirin (81 or 325 mg daily) or placebo (3×2 factorial design) (Appendix E Tables 1 and 2). The study was of fair quality because the relevant outcomes were based on secondary analyses. The main trial found no evidence that folic acid reduced colorectal adenoma incidence and there was some evidence of increased higher-grade adenoma or invasive colorectal cancer; however, these results are not considered in this report, as the study population included individuals with a previous colorectal adenoma. The study is included here for CVD, noncolorectal cancer, and prostate cancer outcomes only.

#### CVD

AFPPS (n=1,021) reported few MIs and strokes, both categorized as adverse events (i.e., a secondary outcome), 10.8 years after randomization; incident rates did not differ between the intervention and control groups (p>0.25 for each outcome).101

#### Cancer

In AFPPS (n=1,021), there were significantly more noncolorectal cancer cases in the intervention group than the control group (p=0.02) (Figure 3).101 In a secondary analysis, AFPPS reported prostate cancer incidence among the 643 men included in the study who were randomized to receive folic acid or placebo (i.e., men randomly assigned to aspirin only were not analyzed).102 Thirty-four prostate cancers were diagnosed; the adjusted probability of this diagnosis was 9.7 percent in the intervention group and 3.3 percent in the control group (HR, 2.58 [95% CI, 1.14 to 5.86]) after 10.8 years. The study investigators attributed the higher rate of noncolorectal cancers in the intervention group to the excess of prostate cancer cases.101

#### All-Cause Mortality

AFPPS (n=1,021) reported all-cause mortality; 10 deaths occurred in the intervention group and 19 in the control group (p=0.09) (Figure 4).101

#### Harms

Except for the increased risk of prostate cancer noted previously, AFPPS (n=1,021) did not report on additional harms with folic acid supplementation.101

### Vitamin D

#### Summary of Results

The beneficial and harmful effects of vitamin D on CVD and cancer were studied in three fair- to good-quality trials (n=8,106) (Table 32).103-105 None of the trials reported on CVD incidence; the only trial that reported on CVD mortality found no effect of vitamin D supplementation. The same trial also found no effect on cancer incidence, cancer mortality, or all-cause mortality. Vitamin D was associated with few adverse effects.

Table 32 Vitamin D Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
RECORD103,106,107 Fair | 2×2 factorial RCT 6.2 years | Vitamin D_3_ 800 IU qd (alone or in combination with calcium 1,000 mg qd) 3.75 years (median) (range, 2 to 5.2 years) | 5,292 | 77 | 85 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: ↔ Breast: ↔ Other: ↔ | ↔ | ↔
Trivedi 2003^104^ Fair | RCT 5 years | Vitamin D_3_ 100,000 IU every 4 months 5 years | 2,686 | 75 | 24 | Any: ↔ MI: NR Stroke: ↔ | Any: ↔ Lung: ↔ CRC: ↔ Prostate: NR Breast: NR Other: NR | ↔^†^ | NR
Dean, 2011^105^ Good | RCT 0.1 years | Vitamin D 5,000 IU qd 0.1 years | 128 | 22 | 57 | NA | NA | NA | ↔

* CVD mortality only.

† Cancer and CVD-related mortality also reported; no significant difference between groups.

Abbreviations: bid = twice daily; CRC = colorectal cancer; CVD = cardiovascular disease; max = maximum; MI = myocardial infarction; NA = not applicable; NR = not reported; qd = once daily; RCT = randomized, controlled trial; RECORD = Randomized Evaluation of Calcium or Vitamin D; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified two RCTs examining the effects of vitamin D (n=7,978) on cancer, CVD, and/or all-cause mortality: the Randomized Evaluation of Calcium or Vitamin D (RECORD)103 and a UK-based study by Trivedi and colleagues (Appendix E Tables 1 and 2).104 The RECORD trial, a 2×2 factorial study, examined the effects of vitamin D_3_ (800 IU daily) and calcium (1,000 mg daily) supplementation.103 It randomized 5,292 participants (mean age, 75 years) with a history of a fragility fracture; 85 percent were female. The study by Trivedi and colleagues examined the effects of 100,000 units of vitamin D_3_ administered orally every 4 months for 5 years.104 It randomized 2,686 healthy participants (mean age, 75 years; 24% women) living in the community; about three quarters were physicians from the British Doctors Study.104 Both trials were also designed to examine fracture outcomes. A third study, by Dean and colleagues, was a short, small trial testing the effects of vitamin D 5,000 IU daily on cognitive and emotional function in young adults.105 We included its data on harms. This trial included 128 healthy men and women recruited at the University of Queensland with a mean age of 22 years.

#### CVD

Two trials (n=7,979) of vitamin D supplementation reported on CVD incidence (Table 33).104,106 The RECORD trial (n=5,292) included fatal CVD as a primary outcome. This trial found no statistically significant effect on any cardiovascular events, MI, stroke, or fatal event between participants receiving vitamin D and those who were not.103 It did, however, find a statistically significant decreased risk for cardiac failure among those taking vitamin D.106 Trivedi and colleagues (n=2,686) also reported CVD incidence (a primary outcome) and related deaths and found no effect with vitamin D supplementation.104

Table 33 Cardiovascular Disease Incidence and Mortality Among Vitamin D Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any CVD incidence | Trivedi 2003^§,104^ | Vitamin D vs. placebo | 5 | 477/1,345 (35.5) | 503/1,341 (37.5) | 0.90^‡^ | 0.77 to 1.06 | 0.22
Any CVD incidence | RECORD106 | Vitamin D vs. no vitamin D | 6.1 | 339/2,649 (12.8) | 363/2,643 (13.7) | 0.96^†^ | 0.82 to 1.13 | 0.61
Ischemic heart disease incidence | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 224/1,345 (16.7) | 233/1,341 (17.4) | 0.94 | 0.77 to 1.15 | 0.57
Cerebrovascular disease incidence | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 105/1,345 (7.8) | 101/1,341 (7.5) | 1.02 | 0.77 to 1.36 | 0.87
Cardiac failure incidence | RECORD106 | Vitamin D vs. no vitamin D | 6.1 | 102/2,649 (3.9) | 136/2,643 (5.1) | 0.73^†^ | 0.55 to 0.96 | 0.03
MI incidence | RECORD106 | Vitamin D vs. no vitamin D | 6.1 | 114/2,649 (4.3) | 117/2,643 (4.4) | 1.04^†^ | 0.79 to 1.37 | 0.76
Stroke incidence | RECORD106 | Vitamin D vs. no vitamin D | 6.1 | 160/2,649 (6.0) | 149/2,643 (5.6) | 1.13^†^ | 0.88 to 1.44 | 0.33
Any CVD death | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 101/1,345 (7.5) | 117/1,341 (8.7) | 0.84 | 0.65 to 1.1 | 0.20
Any CVD death | RECORD103,* | Vitamin D vs. no vitamin D | 6.2 | 350/2,649 (13.2) | 376/2,643 (14.2) | 0.91^†^ | 0.79 to 1.05 | 0.175
Fatal ischemic heart disease | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 42/1,345 (3.1) | 49/1,341 (3.7) | 0.84 | 0.56 to 1.27 | 0.41
Fatal CHD | RECORD103,* | Vitamin D vs. no vitamin D | 6.2 | 162/2,649 (6.1) | 176/2,643 (6.7) | NR | NR | NR
Fatal stroke | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 28/1,345 (2.1) | 26/1,341 (1.9) | 1.04 | 0.61 to 1.77 | 0.89
Fatal stroke | RECORD103,* | Vitamin D vs. no vitamin D | 6.2 | 115/2,649 (4.3) | 105/2,643 (4.0) | NR | NR | NR

* Deaths by other vascular diseases also reported.

† HR, unadjusted.

‡ Adjusted for age.

§ Self-reported incidence or when indicated as cause of death.

Abbreviations: CI = confidence interval; CHD = coronary heart disease; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

#### Cancer

Two trials reported on cancer incidence as primary outcomes (n=7,978). The RECORD trial found similar rates of any and site-specific cancer between those randomized to receive vitamin D and those who were not (Table 34, Figure 3); there were also no statistically significant effects on cancer-related deaths.103 Trivedi and colleagues (n=2,686) also found no effect on cancer incidence or cancer-related deaths with vitamin D supplementation, except on colon cancer-related deaths in women (p=0.04) but not men (p=0.96).104

Table 34 Cancer Incidence and Mortality Among Vitamin D Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any cancer incidence | Trivedi 2003 104,‡ | Vitamin D vs. placebo | 5 | 188/1,345 (14) | 173/1,341 (12.9) | 1.09^†^ | 0.86 to 1.36 | 0.47
Any cancer incidence | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 369/2,649 (13.9) | 354/2,643 (13.4) | 1.07^*^ | 0.92 to 1.25 | 0.376
Breast cancer incidence | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 43/2,649 (1.6) | 37/2,643 (1.4) | NR | NR | NR
Colorectal cancer incidence | Trivedi 2003^104,§^ | Vitamin D vs. placebo | 5 | 28/1,345 (2.1) | 27/1,341 (2.0) | 1.02 | 0.6 to 1.74 | 0.94
Colorectal cancer incidence | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 41/2,649 (1.5) | 30/2,643 (1.1) | NR | NR | NR
Lung cancer incidence | Trivedi 2003^104,‖^ | Vitamin D vs. placebo | 5 | 17/1,345 (1.3) | 15/1,341 (1.1) | 1.12 | 0.56 to 2.25 | 0.75
Lung cancer incidence | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 24/2,649 (0.9) | 32/2,643 (1.2) | NR | NR | NR
Prostate cancer incidence | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 17/2,649 (0.6) | 12/2,643 (0.5) | NR | NR | NR
Any cancer death | Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 63/1,345 (4.7) | 72/1,341 (5.4) | 0.86 | 0.61 to 1.2 | 0.37
Any cancer death | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 151/2,649 (5.7) | 178/2,643 (6.7) | 0.85^*^ | 0.68 to 1.06 | 0.157
Breast cancer death | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 14/2,649 (0.5) | 13/2,643 (0.5) | NR | NR | NR
Colorectal cancer death | Trivedi 2003^104,§^ | Vitamin D vs. placebo | 5 | 7/1,345 (0.5) | 11/1,341 (0.8) | 0.62 | 0.24 to 1.6 | 0.33
Colorectal cancer death | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 20/2,649 (0.8) | 13/2,643 (0.5) | NR | NR | NR
Lung cancer death | Trivedi 2003^104^ ‖ | Vitamin D vs. placebo | 5 | 10/1,345 (0.7) | 11/1,341 (0.8) | 0.89 | 0.38 to 2.09 | 0.78
Lung cancer death | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 24/2,649 (0.9) | 34/2,643 (1.3) | NR | NR | NR
Prostate cancer death | RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 6/2,649 (0.2) | 6/2,643 (0.2) | NR | NR | NR

* HR, unadjusted.

‡ RR adjusted by age.

† Incidence number of cancers excluding skin cancer also reported; no significant difference between groups.

§ Colon cancer only.

‖ Respiratory cancers.

Abbreviations: CI = confidence interval; HR = hazard ratio; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

#### All-Cause Mortality

Two trials provided all-cause mortality data (n=7,978) (Figure 4).103,104 There were fewer deaths in the vitamin D arm of the Trivedi study than in the placebo arm; however, the age-adjusted RR was not statistically significant (Table 35).104 In RECORD, similar mortality rates were seen among those randomized to vitamin D and those randomized to no vitamin D (31.6% vs. 33.3%).103 The overall test for a main effect of vitamin D on all-cause mortality was not significant (HR, 0.93 [95% CI, 0.85 to 1.02]).

Table 35 All-Cause Mortality Among Vitamin D Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR or HR | 95% CI | P-value
Trivedi 2003^104^ | Vitamin D vs. placebo | 5 | 224/1,345 (16.7) | 247/1,341 (18.4) | 0.88^†^ | 0.74 to 1.06 | 0.18
RECORD103 | Vitamin D vs. no vitamin D | 6.2 | 836/2,649 (31.6) | 881/2,643 (33.3) | 0.93^*^ | 0.85 to 1.02 | 0.132

* HR; unadjusted.

† Adjusted for age.

Abbreviations: CI = confidence interval; HR = hazard ratio; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

#### Harms

Vitamin D supplementation was not associated with any statistically significant harms among two trials (n=5,420).103,105 One control participant in the study by Dean and colleagues reported one episode of transient rectal bleeding, and there were no significant differences between groups on the Treatment Emergent Symptom Scale, a 31-item self-report questionnaire capturing a range of potential adverse effects, after 6 weeks of followup (p=0.26).105 In the RECORD trial, renal insufficiency developed in seven participants, renal stones in four, and hypercalcemia in 21 (data were not stratified by arm), but there were no significant differences between the treatment arms after 5 years followup.103 There were no significant differences in serious adverse events between groups, with 13.7 percent of those randomized to receive vitamin D and 14.5 percent of those randomized to receive no vitamin D reporting side effects.107

### Vitamin D and Calcium

#### Summary of Results

We identified one fair-quality and one good-quality trial examining the combination supplement of vitamin D and calcium (n=37,462) (Table 36).108,109 The simplest interpretation of the results from these two trials is that the combination supplement most likely has no effect on CVD or cancer. The best evidence of a benefit from vitamin D comes from the study by Lappe and colleagues, conducted in rural Nebraska, where vitamin D levels are known to be low, and used a dose of vitamin D that was 2.5 times greater than that used in WHI; this study found a statistically significant decreased risk of any cancer with supplement use (p=0.018). This was a small study (n=1,180), however, and we rated it as only fair quality.

Table 36 Vitamin D and Calcium Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
Lappe 2007^109,175^ Fair | RCT 4 years | Vitamin D_3_ 25 mcg qd + calcium 1,400 mg qd 4 years | 1,180 | 67 | 100 | NR | Any: ↓ Lung: ↔ CRC: ↔ Prostate: NA Breast: ↔ Other: ↔ | NR | ↔
WHI108,110-112,137,176-185 Good | RCT 7 years | Vitamin D_3_ 200 IU bid + calcium 500 mg bid 7 years (mean) | 36,282 | 62 | 100 | Any: ↔ MI: ↔ Stroke: ↔ | Any: ↔ Lung: NR CRC: ↔ Prostate: NA Breast: ↔ Other: ↔ | ↔ | ↑ | Kidney stones (↑)

Abbreviations: bid = twice daily; CRC = colorectal cancer; CVD = cardiovascular disease; MI = myocardial infarction; NA = not applicable; NR = not reported; qd = once daily; RCT = randomized, controlled trial; WHI = Women's Health Initiative; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified one good-quality108 and one fair-quality109 RCT that studied the combination of vitamin D and calcium (Appendix E Tables 1 and 2). These trials were designed to test the effects of this supplementation on fracture risk and mortality; CVD was a prespecified outcome for WHI.108 The study by Lappe and colleagues recruited 1,180 women (mean age, 62 years) from rural Nebraska, where vitamin D levels are known to be low but not necessarily deficient.109 It randomized women to receive calcium alone (1,400 to 1,500 mg daily), vitamin D (1,000 IU or 25 mcg daily) in combination with calcium, or placebo. We rated this trial as fair quality because the reports lacked detail about allocation concealment, blinding of outcome ascertainment, and differential followup. WHI was also limited to women (mean age, 68 years) but was much larger, with 36,282 participants randomized to vitamin D (200 IU or 5 mcg twice daily) and calcium (500 mg twice daily) or placebo. We rated it as good quality.108 It was designed to primarily examine vitamin D and calcium supplementation for preventing hip fractures and secondarily other fractures and colorectal cancer.

#### CVD

Only WHI (n=26,282) reported CVD incidence and mortality (primary outcomes included MI, angina, stroke, and cardiovascular-related death) and found no effect with the combination supplement (Table 37; Figure 2).108 The WHI investigators also examined the incidence of diabetes and found no effect with supplementation (HR, 1.01 [95% CI, 0.94 to 1.10]; data not shown).110

Table 37 Cardiovascular Disease Incidence and Mortality Among Combined Vitamin D and Calcium Supplement Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | HR^†^ | 95% CI | P-value
Any CVD incidence^‡^ | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 1,832/18,176 (10.1) | 1,810/18,106 (10.0) | 1.00 | 0.94 to 1.07
Any heart disease incidence^*^ | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 1,405/18,176 (7.7) | 1,363/18,106 (7.5) | 1.02 | 0.95 to 1.11
CHD incidence^‖^ | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 499/18,176 (2.7) | 475/18,106 (2.6) | 1.03^†^ | 0.90 to 1.17
MI incidence | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 411/18,176 (2.3) | 390/18,106 (2.2) | 1.05 | 0.91 to 1.20 | 0.52
Angina incidence | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 404/18,176 (2.2) | 377/18,106 (2.1) | 1.08 | 0.94 to 1.24 | 0.30
Stroke incidence^§^ | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 362/18,176 (2) | 377/18,106 (2.1) | 0.95 | 0.82 to 1.10 | 0.51
Heart failure (hospital) incidence | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 394/18,176 (2.2) | 407/18,106 (2.2) | 0.95 | 0.83 to 1.10 | 0.50
TIA incidence | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 213/18,176 (1.2) | 182/18,106 (1) | 1.16 | 0.95 to 1.42 | 0.13
Any CVD death | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 226/18,176 (1.2) | 244/18,106 (1.3) | 0.92 | 0.77 to 1.10 | NR
Fatal CHD | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 130/18,176 (0.7) | 128/18,106 (0.7) | 1.01 | 0.79 to 1.29 | 0.52
Fatal MI or CHD | WHI 112,181,183 | Vitamin D + calcium vs. placebo | 7 | 499/18,176 (2.7) | 475/18,106 (2.6) | 1.04 | 0.92 to 1.18 | NR

* Total heart disease includes CHD, revascularization, angina, and congestive heart failure.

† HR, unadjusted.

‡ Total CVD includes total heart disease, stroke, carotid artery disease, and peripheral vascular disease.

§ Ischemic, hemorrhagic, and other stroke also reported.

‖ Included nonfatal MI and CHD death.

Abbreviations: CI = confidence interval; CHD = coronary heart disease; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; TIA = transient ischemic attack; WHI = Women's Health Initiative; y = years.

#### Cancer

Two trials (n=37,462) reported on cancer incidence and mortality with mixed results (Table 38; Figure 3).108,109 The study by Lappe and colleagues found a statistically significant reduction in the incidence of any cancer (p=0.013) after 4 years of vitamin D in combination with calcium supplementation.109 This result is similar in magnitude to the findings in the calcium-only arm (discussed below), but for calcium the difference was not statistically significant. There were fewer breast, colon, lung, uterine, lymph, leukemia, and myeloma cancer cases in the intervention group than the placebo group (data not shown). WHI found no effect of the combination supplement on any cancer incidence (total or site-specific) or mortality rates.108 A post hoc subgroup analysis of the WHI data showed that vitamin D in combination with calcium supplementation was associated with lower total cancer and breast cancer incidence among women who were not taking either supplement at baseline.111

Table 38 Cancer Incidence and Mortality Among Combined Vitamin D and Calcium Supplement Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any cancer incidence | Lappe 2007^109^ | Vitamin D + calcium vs. placebo | 4 | 13/446 (2.9) | 20/288 (6.9) | 0.402 | 0.20 to 0.82 | 0.013
Any cancer incidence | WHI108 | Vitamin D + calcium vs. placebo | 7 | 1,634/18,176 (9.0) | 1,655/18,106 (9.1) | 0.98^*^ | 0.91 to 1.05 | 0.53
Breast cancer incidence | Lappe 2007^109^ | Vitamin D + calcium vs. placebo | 4 | 5/446 (1.1) | 8/228 (2.8) | NR | NR | NR
Breast cancer incidence | WHI178 | Vitamin D + calcium vs. placebo | 7 | 668/18,176 (3.7) | 693/18,106 (3.8) | 0.96^*^ | 0.86 to 1.07 | NR
Colorectal cancer incidence | Lappe 2007^109^ | Vitamin D + calcium vs. placebo | 4 | 1/446 (0.2) | 2/228 (0.9) | NR | NR | NR
Colorectal cancer incidence | WHI108 | Vitamin D + calcium vs. placebo | 7 | 168/18,176 (0.9) | 154/18,106 (0.9) | 1.08^*^ | 0.86 to 1.34 | 0.51
Lung cancer incidence | Lappe 2007^109^ | Vitamin D + calcium vs. placebo | 4 | 1/446 (0.2) | 3/228 (1.3) | NR | NR | NR
Any cancer death | WHI108 | Vitamin D + calcium vs. placebo | 7 | 344/18,176 (1.9) | 385/18,106 (2.1) | 0.89^*^ | 0.77 to 1.03 | 0.12
Breast cancer death | WHI178 | Vitamin D + calcium vs. placebo | 7 | 23/18,176 (0.1) | 23/18,106 (0.1) | 0.99^*^ | 0.55 to 1.76 | NR
Colorectal cancer death | WHI108 | Vitamin D + calcium vs. placebo | 7 | 34/18,176 (0.2) | 41/18,106 (0.2) | 0.82^*^ | 0.52 to 1.29 | 0.39

* HR.

Abbreviations: CI = confidence interval; HR = hazard ratio; NR = not reported; RR = relative risk; WHI = Women's Health Initiative; y = years.

#### All-Cause Mortality

Only WHI (n=36,282) reported on all-cause mortality. It found no effect with the combination supplement after 7 years of followup (Table 39, Figure 4).

Table 39 All-Cause Mortality Among Combined Vitamin D and Calcium Supplement Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | HR^*^ | 95% CI | P-value
WHI108 | Vitamin D + calcium vs. placebo | 7 | 744/18,176 (4.1) | 807/18,106 (4.5) | 0.91 | 0.83 to 1.01 | 0.07

* HR; unadjusted.

Abbreviations: CI = confidence interval; HR = hazard ratio; WHI = Women's Health Initiative; y = years.

#### Harms

Two trials reported on harms (n=37,462). The Lappe study reported no serious supplement-related adverse events and found no differences between groups for any outcome, including renal calculi, which was the most serious adverse event reported.109 WHI reported a small increase in kidney stones in the combination supplement group compared with the placebo group (449 vs. 381; HR, 1.17 [95% CI, 1.02 to 1.34]); no other statistically significant different adverse outcomes were reported.108 WHI also reported no statistically significant difference in the number of hip or total fractures (data not shown).112

### Calcium

#### Summary of Results

Four trials (n=8,873) of calcium found no effect on overall CVD, cancer, or all-cause mortality (Table 40).103,113,114 When data from two studies were pooled, calcium supplementation was associated with an increased risk of developing colorectal cancer (unadjusted Peto OR, 1.71 [95% CI, 1.08 to 2.72]) (Appendix G, Figure 7). Calcium supplementation was also frequently associated with side effects (e.g., constipation). Only one trial reported a significant increase in hip fractures in the calcium group, but it also reported fewer fractures at other sites, so the overall fracture rates were similar between treatment groups. None of the other RCTs reported differences between groups on fracture rates.115

Table 40 Calcium Evidence Summary

Study Quality | Study design Followup (max) | Supplement and dose Supplement duration | N | Mean age (y) | % Female | CVD incidence | Cancer incidence | Mortality | Harms | Comments
ACS 113,115,186 Fair | RCT 5 years | Calcium 1,000 mg qd 5 years | 1,471 | 74 | 100 | Any: ↔ MI: ↔ Stroke: ↔ | NR | ↔ | ↑ | Constipation (↑) and hip fractures (↑)
Lappe 2007^109^ Fair | RCT 4 years | Calcium 1,400 mg qd 4 years | 1,180 | 67 | 100 | NR | Any: ↔ Lung: ↔ CRC: ↔ Prostate: NA Breast: ↔ Other: | NR | ↔
CPPS114,116 Fair | RCT 12 years | Calcium 1,200 mg bid 4 years | 930 | 61 | 28 | Any: ↔ MI: NR Stroke: ↔ | Any: ↔ Lung: NR CRC: NR Prostate: ↔ Breast: NA Other: NR | ↔ | ↔
RECORD103,107 Fair | 2×2 factorial RCT 6.2 years | Calcium 1,000 mg qd (alone or in combination with vitamin D_3_ 800 IU qd) 3.75 years (median) (range, 2 to 5.2 years) | 5,292 | 77 | 85 | Any: ↔^*^ MI: NR Stroke: NR | Any: ↔ Lung: ↔ CRC: ↑ Prostate: ↔ Breast: ↔ Other: ↔ | ↔ | ↔

* CVD mortality only.

Abbreviations: ACS = Auckland Calcium Study; bid = twice daily; CPPS = Calcium Polyp Prevention Study; CRC = colorectal cancer; CVD = cardiovascular disease; max = maximum; MI = myocardial infarction; NA = not applicable; NR = not reported; qd = once daily; RCT = randomized, controlled trial; RECORD = Randomized Evaluation of Calcium or Vitamin D; y = years.

Legend: ↑ (statistically significant increase in risk of outcome from supplementation), ↔ (no statistically significant difference between intervention groups), ↓ (statistically significant decrease in risk of outcome from supplementation).

#### Study Details

We identified four fair-quality RCTs that reported data on CVD, cancer, or both after calcium supplementation (Appendix E Tables 1 and 2): the Auckland Calcium Study (ACS),113 the Calcium Polyp Prevention Study (CPPS),114 the RECORD trial (discussed previously),103 and the study conducted in Nebraska by Lappe and colleagues (discussed previously).109

The data we included from ACS and RECORD were secondary analyses of RCTs that were designed to evaluate fracture prevention.103,113 The data we included from CPPS (cancer, strokes, and mortality) were secondary outcomes of an RCT designed to evaluate the impact of calcium supplementation on recurrent colorectal polyps.114 The study by Lappe and colleagues primarily evaluated fracture prevention but also evaluated cancer incidence as a secondary endpoint. Its interventions included a combination supplementation (calcium in combination with vitamin D) and calcium alone.109

The 2×2 factorial-designed RECORD trial randomized participants age 70 years or older (n=5,292) to calcium (1,000 mg daily) or vitamin D_3_ (800 IU daily) and comprised 85 percent women.103 ACS recruited only postmenopausal women older than age 55 years (n=1,471) and randomized them to 1 g of daily calcium or placebo.113 CPPS was designed to study the effects of calcium carbonate (1,200 mg daily) on colorectal adenoma recurrence (n=930); a secondary analysis investigated the risk of prostate cancer among the 672 men in the original trial.114 The trial by Lappe and colleagues was conducted among 1,108 women (mean age, 67 years) in rural Nebraska, where vitamin D levels are generally low, and used a calcium dose of 1,500 mg daily.109

#### CVD

Two trials reported CVD incidence (n=2,110) (Table 41).113,116 ACS measured any adverse cardiovascular event over 5 years and found more cases of adjudicated and verified MI and stroke in the calcium group, but the differences were not statistically significant. The composite endpoint of MI, stroke, and sudden death occurred in 60 women in the calcium group and 50 in the control group (p=0.32).113 There was also no difference between groups on the incidence of other cardiovascular events (angina, other chest pain, or transient ischemic attack), which were reported only by participants or their families (data not shown). The CVD mortality rate was 50 percent lower in the calcium group, but there were only nine events and the difference was not significant.113 In CPPS, there were no significant differences between groups in the number of participants hospitalized for stroke or cardiac disease (secondary endpoints).116 The RECORD trial (n=5,292) included all “vascular” deaths, from cardiovascular, cerebrovascular, and other vascular disease. The RECORD investigators found a nonsignificant increase in vascular disease mortality (HR, 1.07 [95% CI, 0.92 to 1.24]) associated with calcium supplementation.

Table 41 Cardiovascular Disease Incidence and Mortality Among Calcium Studies

Outcome^‡^ | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
MI incidence | ACS113,‡ | Calcium vs. placebo | 5 | 31/732 (4.2) | 21/739 (2.8) | 1.49^*^ | 0.86 to 2.57 | 0.16
Stroke incidence | ACS113,‡ | Calcium vs. placebo | 5 | 34/732 (4.6) | 25/739 (3.4) | 1.37^†^ | 0.83 to 2.28 | 0.23
Stroke incidence | CPPS114,¶ | Calcium vs. placebo | 4 | 12/464 (3) | 11/466 (2) | NR | NR | NSD
Any CVD death^§^ | ACS113,‡ | Calcium vs. placebo | 5 | 3/732 (0.4) | 6/739 (0.8) | 0.51^#^ | 0.13 to 2.01 | 0.51
Any CVD death^§^ | RECORD 103,§ | Calcium vs. no calcium | 6.2 | 371/2,617 (14.2) | 355/2,675 (13.3) | 1.07^‖^ | 0.92 to 1.24 | 0.333
Fatal CHD | RECORD103 | Calcium vs. no calcium | 6.2 | 179/2,617 (6.8) | 159/2,675 (5.9) | NR | NR | NR
Fatal stroke | RECORD103 | Calcium vs. no calcium | 6.2 | 110/2,617 (4.2) | 110/2,675 (4.1) | NR | NR | NR

* Incidence rate ratio, 1.67 (95% CI, 0.98 to 2.87); p=0.058.

† Incidence rate ratio, 1.45 (95% CI, 0.88 to 2.49); p=0.15.

‡ Adjudicated and verified vascular events (participant report, reported by family member, or from national database of hospital admissions). Angina, other chest pain, and transient ischemic attack were also reported as potential vascular events; however, since they were reported by participants or family only (i.e., not adjudicated or verified), they are not shown here.

§ Also reported deaths for other vascular diseases in RECORD.

‖ HR.

¶ Hospitalizations.

# Mortality rate ratio, 0.51 (95% CI, 0.10 to 2.04); p=0.36.

Abbreviations: ACS = Auckland Calcium Study; CI = confidence interval; CHD = coronary heart disease; CPPS = Calcium Polyp Prevention Study; CVD = cardiovascular disease; HR = hazard ratio; MI = myocardial infarction; NR = not reported; NSD = no significant difference; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

#### Cancer

Cancer outcomes were available from three trials (n=7,693) (Table 42).103,109,114 The trial conducted by Lappe and colleagues reported a lower incidence of any cancer in the calcium group compared with the placebo group (3.8% vs. 6.9%); however, this finding was based on a total of 37 events and the difference did not attain statistical significance (p=0.063). The magnitude of the reduction was similar in the calcium plus D arm (reported previously), where the difference was significant. Site-specific cancer incidence rates were based on even fewer events and showed no statistically significant differences.109 In RECORD, the rate of any cancer in participants randomized to receive calcium was similar to the rate in those who did not receive calcium; the number of site-specific cancers, however, was sometimes higher in the calcium group, but no statistical testing was performed. When data from two trials were pooled, calcium supplementation was associated with an increased risk for developing colorectal cancer (unadjusted Peto OR, 1.71 [95% CI, 1.08 to 2.72]) (Appendix G, Figure 7). This finding, however, is based on a total of only 73 cases (46 in intervention group and 27 in control group). CPPS found no significant difference between groups on any cancer incidence after 4 years. This trial also reported on prostate cancer incidence among the 672 men in the original trial and found no significant difference between the calcium and placebo groups after 10 years of followup.114 The number of subjects hospitalized due to cancer was not significantly different between groups (data not shown).116 Cancer mortality was reported only in RECORD (n=5,292) (Table 38); the main effect analysis of calcium supplementation showed no effect on any or site-specific cancer deaths.103

Table 42 Cancer Incidence and Mortality Among Calcium Studies

Outcome | Study | Comparison | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR or HR | 95% CI | P-value
Any cancer incidence | Lappe 2007^109^ | Calcium vs. placebo | 4 | 17/445 (3.8) | 20/288 (6.9) | 0.532 | 0.27 to 1.03 | 0.063
Any cancer incidence | CPPS116 | Calcium vs. placebo | 4 | 15/464 (3) | 21/466 (5) | NR | NR | NSD
Any cancer incidence | RECORD103 | Calcium vs. no calcium | 6.2 | 371/2,617 (14.2) | 352/2,675 (13.2) | 1.06^†^ | 0.91 to 1.23 | 0.485
Breast cancer incidence | Lappe 2007^109^ | Calcium vs. placebo | 4 | 6/445 (1.3) | 8/288 (2.8) | NR | NR | NR
Breast cancer incidence | RECORD103 | Calcium vs. no calcium | 6.2 | 41/2,617 (1.6) | 39/2,675 (1.5) | NR | NR | NR
Colorectal cancer incidence | Lappe 2007^109^ | Calcium vs. placebo | 4 | 0/445 (0) | 2/288 (0.7) | NR | NR | NR
Colorectal cancer incidence | RECORD103 | Calcium vs. no calcium | 6.2 | 46/2,617 (1.8) | 25/2,675 (0.9) | NR | NR | NR
Lung cancer incidence | Lappe 2007^109^ | Calcium vs. placebo | 4 | 3/445 (0.7) | 3/288 (1.4) | NR | NR | NR
Lung cancer incidence | RECORD103 | Calcium vs. no calcium | 6.2 | 24/2,617 (0.9) | 32/2,675 (1.2) | NR | NR | NR
Prostate cancer incidence | CPPS114 | Calcium vs. placebo | 10.3 | 33/345 (9.6) | 37/327 (11.3) | 0.83^*^ | 0.52 to 1.32 | NR
Prostate cancer incidence | RECORD103 | Calcium vs. no calcium | 6.2 | 12/2,617 (0.5) | 17/2,675 (0.6) | NR | NR | NR
Any cancer death | RECORD103 | Calcium vs. no calcium | 6.2 | 173/2,917 (5.9) | 156/2,675 (5.8) | 1.13^†^ | 0.91 to 1.40 | 0.249
Breast cancer death | RECORD103 | Calcium vs. no calcium | 6.2 | 16/2,917 (0.5) | 11/2,675 (0.4) | NR | NR | NR
Colorectal cancer death | RECORD103 | Calcium vs. no calcium | 6.2 | 20/2,917 (0.7) | 13/2,675 (0.5) | NR | NR | NR
Lung cancer death | RECORD103 | Calcium vs. no calcium | 6.2 | 27/2,917 (0.9) | 31/2,675 (1.2) | NR | NR | NR
Prostate cancer death | RECORD103 | Calcium vs. no calcium | 6.2 | 5/2,917 (0.2) | 7/2,675 (0.3) | NR | NR | NR

* Rate ratio; also reported between baseline and year 6 (risk ratio, 0.52 [95% CI, 0.28 to 0.98]) and year 2 to year 6 (risk ratio, 0.44 [95% CI, 0.21 to 0.94]).

† HR.

Abbreviations: CI = confidence interval; CPPS = Calcium Polyp Prevention Study; HR = hazard ratio; NR = not reported; NSD = no significant difference; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years

#### All-Cause Mortality

Three trials (n=7,693) found no statistically significant differences between groups for all-cause mortality (Table 43, Figure 4).103,113,116

Table 43 All-Cause Mortality Among Calcium Alone vs. Placebo Studies

Study | Comparison | Mean followup (y) | Intervention, # of deaths (%) | Comparator, # of deaths (%) | RR or HR | 95% CI | P-value
ACS113 | Calcium vs. placebo | 5 | 34/732 (4.6) | 29/739 (3.9) | 1.18 | 0.73 to 1.92 | 0.52
CPPS116 | Calcium vs. placebo | 4 | 25/464 (5) | 22/466 (5) | NR | NR | NSD
RECORD103,* | Calcium vs.no calcium | 6.2 | 862/2,617 (32.9) | 855/2,675 (32) | 1.03^*^ | 0.94 to 1.13 | 0.460

* HR.

Abbreviations: ACS = Auckland Calcium Study; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; HR = hazard ratio; NR = not reported; NSD = no significant difference; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

#### Harms

Few adverse effects were reported by four trials (n=8,873).103,109,113,114 The Lappe study reported no serious supplement-related adverse events and no differences between groups for any outcomes, including renal calculi, which was the most serious adverse event reported.109 ACS found higher rates of constipation in the calcium group (18% vs. 11%; p=0.0002). The discontinuation rate was also higher (46% vs. 40%; p=0.02) and was attributed to the higher rates of constipation in the intervention group.115 In CPPS, the frequency of digestive symptoms (e.g., constipation) did not differ between the calcium and placebo groups; three patients experienced urinary stones.116 In addition, 3 percent of participants discontinued due to perceived toxicity during the study.

In RECORD, after 5 years of followup, study investigators noted poorer compliance with calcium supplementation that reflected more frequent decisions to stop supplementation due to gastrointestinal symptoms. More side effects were reported among participants taking calcium than those who were not (16.4% vs. 11.9%).107 Renal insufficiency developed in seven participants, renal stones in four, and hypercalcemia in 21; these data were not reported separately by arm, but the investigators stated that there were no significant differences between the treatment arms after 5 years followup.

ACS also reported a significant increase in hip fractures in the calcium group: 17 in the calcium group and five in the control group (HR, 3.55 [95% CI, 1.31 to 9.63]). Fewer fractures occurred at other sites in the intervention group and the overall fracture rates were similar between the two groups (HR, 0.91 [95% CI, 0.71 to 1.17]).115

### Summary of Pooled Data

Figures 2–4 summarize the results of this review across all supplements studied for any CVD incidence, any cancer incidence, and all-cause mortality. These figures make two main points. First, the opportunity for pooling is limited due to the limited number of studies. Second, there is little evidence of a dramatic effect of any of the supplements on any of the outcomes, even the one exception of any cancer incidence being lower in the two multivitamin supplement studies49,50 (these figures depict both sexes, but the results for men only are nearly identical; data not shown). Additional figures are provided in Appendix G. The results from our meta-analysis may differ from those reported in original trials, as we used raw data and calculated unadjusted RRs and ORs.