# Methods

AHRQ commissioned this evidence review on the use of multivitamins for the primary prevention of cancer and CVD in the general population to assist the USPSTF in updating its 2003 recommendation on routine vitamin supplementation. Our review is similar in scope to the three 2003 evidence reviews37-39 the USPSTF used to develop its previous recommendation statement.1 These reviews, however, included a limited number of individual and combination vitamins and minerals (vitamins A, E, and C, “antioxidant combinations,” and “multivitamin preparations”) compared with our review, which includes additional supplements (e.g., calcium, vitamin D, folic acid). In addition, the previous reviews included any primary or secondary prevention study of vitamins or minerals that reported on the incidence or mortality of cancer38 or CVD,37 whereas our review focused on primary prevention.

In 2006, Huang and colleagues conducted a comprehensive and good-quality systematic review for a National Institute of Health State-of-the-Science Conference on the efficacy and safety of multivitamin and mineral supplement use to prevent cancer and chronic disease in adults.40 This review focused on the prevention of all chronic conditions, including CVD and cancer. We used this existing review as the foundation for our current review.

## Key Questions and Analytic Framework

We developed an analytic framework (Figure 1) and four Key Questions (KQs) to guide our literature searches in consultation with members from the USPSTF. This review addressed the following KQs:

1. What is the efficacy of multivitamin supplement use on health outcomes in the general adult population?
2. What is known about the safety of multivitamin supplement use in the general adult population?
3. What is the efficacy of supplementation with single nutrients or functionally related nutrient pairs on health outcomes in the general adult population?
4. What is known about the safety of single nutrient use in the general adult population?

Figure 1 Analytic Framework

* Only includes intermediate outcomes (e.g., biomarkers) in trials reporting disease incidence.

Figure 1 is an analytic framework that depicts the four Key Questions described in the Methods section of the report. In general, the figure illustrates how the use of multivitamin supplementation, single or paired nutrients, among the general adult population may result in changes in cardiovascular disease, cancer, and all-cause mortality, as well as possible harms.

## Data Sources and Searches

We performed comprehensive literature searches in the following databases: MEDLINE, EMBASE, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, and Cochrane Central Register of Controlled Trials from 2005 through January 29, 2013 to identify studies published since the 2006 review by Huang and colleagues. We worked with an expert library scientist to develop comprehensive literature search strategies (Appendix B). We limited all searches to articles published in the English language. The literature search results were managed using version 12.0 of Reference Manager (Thomson Reuters, New York, NY).

We reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before the timeframe of our literature searches or were not identified by our searches to ensure our retrieval strategy was comprehensive. We obtained references from outside experts and bibliographies of other relevant sources (e.g., dietary guidelines). We also searched Federal agency trial registries for ongoing and/or unpublished trials (Appendix C). We conducted a search of the grey literature that included summary reports from the Center for Food Safety and Nutrition Adverse Events Reporting System. We also evaluated all studies included and excluded in the four previous reviews against the inclusion and exclusion criteria for the current review.37-40 As a result, we included 10 studies from the previous reviews (published in 30 articles). We also conducted a supplementary search examining dietary supplements to prevent diabetes mellitus.

For KQs 1 and 3 (efficacy), we restricted the searches to include only RCTs, systematic reviews, and meta-analyses. For KQs 2 and 4 (safety), we expanded our searches to include observational studies (e.g., cohort or registry-based studies) and postmarketing surveillance data.

## Study Selection

Two reviewers independently reviewed the titles and abstracts of all identified articles against inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix B Table 1). Two reviewers independently evaluated the full-text article(s) of all potentially included studies against the complete inclusion and exclusion criteria (Appendix B Table 1). We resolved disagreements in the abstract and/or full-text review through discussion and consultation with a third reviewer.

For efficacy (KQs 1 and 3), we included primary prevention trials (i.e., prevention of development of disease in a population or individual who is well and does not have the disease in question)41 that addressed the outcomes of interest to the USPSTF. These outcomes included any CVD incidence (e.g., coronary heart disease, ischemic heart disease, coronary artery disease, atherosclerotic heart disease, atherosclerosis, and diabetes), cardiomyopathy, angina pectoris (i.e., chest pain), MI, stroke (both ischemic and hemorrhagic and cerebrovascular accidents), heart failure and related mortality, cancer incidence and related mortality, and all-cause mortality. We included only trials that addressed these as a priori outcomes and included a general population not selected due to poor nutrition. Because of the generally limited number of primary prevention trials, we also included trials that evaluated secondary prevention (i.e., prevention of disease in individuals with a previous diagnosis or serious risk factors) if the study also hypothesized effects on other outcomes. For example, the Skin Cancer Prevention Study (SCPS), the Retinoid Skin Cancer Prevention trials (Skin Cancer Prevention-Actinic Keratoses [SKICAP-AK] and Skin Cancer Prevention-SCC/BCC [SKICAP-S/B]), and the Nambour Skin Cancer and Actinic Eye Disease Prevention trial were designed to prevent skin cancer in patients with a prior history of basal cell carcinoma (BCC) and/or squamous cell carcinoma (SCC) of the skin with a vitamin or mineral supplement. We included these trials because they also hypothesized that supplementation might impact other cancers and mortality. For these studies, we only considered nonskin cancer and only used all-cause mortality and/or harms data (if reported) in our synthesis. We also excluded tertiary prevention trials (i.e., prevention of complications or recurrence of a disease in a symptomatic person who has been diagnosed with the disease). For mortality, we also included studies designed to prevent other diseases if they reported all-cause mortality data as a primary aim. We did not include any reported CVD or cancer outcomes for studies whose primary aim was not to prevent these two conditions. For harms, we included any trial that reported on adverse events, regardless of its aim.

We included studies that examined the efficacy of multivitamins (KQs 1 and 2); calcium; folic acid; vitamins B_1_, B_2_, B_6_, B_12_, E, C, A, and D; iron; zinc; magnesium; niacin; calcium/magnesium; calcium/vitamin D; folic acid/vitamin B_12_; and folic acid/vitamin B_6_ (KQ 3). For examination of safety (KQ 4), we specifically focused on the following supplements that had hypothesized harms: calcium; folic acid; vitamin D; calcium/vitamin D, E, and A; iron; selenium; and beta-carotene.

We only included studies that tested supplements at doses lower than their tolerable upper intake level. As such, we excluded studies evaluating high-dose vitamin therapy. This decision reflects our focus on recommendations for preventive vitamin and mineral supplementation, as opposed to therapeutic supplementation. Appendix A Table 1 lists the RDA and upper intake levels for the micronutrients we included in the review.

For KQs 1 and 3, we selected RCTs in community-dwelling adults (age 18 years or older) who did not have chronic disease or nutritional deficiencies. We included populations with hypertension and/or hypercholesterolemia as long as they did not have known CVD (e.g., coronary, cerebrovascular, or peripheral artery disease) or diabetes. We excluded studies in which 10 percent or more of participants had active/current CVD, diabetes mellitus, or cancer, as we did not want a significant proportion of the study population to have chronic diseases and to reduce any confounders.

For KQs 2 and 4, we selected RCTs or longitudinal observational studies (e.g., prospective cohort studies) in community-dwelling adults who were without chronic disease or nutritional deficiencies. We included observational studies to increase the likelihood of detecting harms that are rare or that develop only after long time periods.42 We focused on important harms by including only those adverse events that were reported in more than 5 percent of the study population or met the definition of serious events used by the study investigators and that occurred at a significantly higher rate in the intervention group(s). Furthermore, we did not include observational study data on the main outcomes being examined—CVD, cancer, and all-cause mortality—but rather included only RCT data for these outcomes, whether beneficial or (paradoxically) harmful.

We only included studies that were conducted in countries the Human Development Index classifies as “very high” to avoid the possibility of widespread nutritional deficiencies in other countries.43 Supplementation in a nutrient-deficient population would be considered treatment of a disorder, and therefore was excluded.

## Quality Assessment

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF44 and supplemented with the National Institute for Health and Clinical Excellence methodology checklists for observational studies (Appendix B Table 2).45 We resolved disagreements in quality through discussion. We assigned each study a final quality rating of good, fair, or poor.

Good-quality RCTs were those with adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., little to no statistically significant differences between groups in baseline demographics and characteristics), low attrition (≥90% of participants had followup data, with <10 percentage-point difference in loss to followup between groups), and those that used conservative data-substitution methods if missing data were inferred. Trials were downgraded to fair quality if they did not meet the majority of the good-quality criteria. We rated trials as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there were any other important “fatal” flaws that two independent investigators agreed seriously affected internal validity. Poor-quality studies were excluded from the review (Appendix D).

Good-quality observational studies had an unbiased selection of the nonexposed cohort, adequate ascertainment of exposure, addressed a population without the outcome of interest at the beginning of the study, reliable outcome measures, blinded assessment, low attrition, adjustment for potential confounders, and no other important threats to internal validity. Observational studies were downgraded to fair quality if they were unable to meet the majority of good-quality criteria. Poor-quality observational studies had multiple threats to internal validity and were excluded from the review.

## Data Extraction

One reviewer abstracted data from all included studies rated as fair- or good-quality into a standard evidence table and a second reviewer checked the data for accuracy. We abstracted population characteristics (e.g., baseline demographics, body mass index, concurrent conditions, family history of cancer or CVD, smoking status, alcohol use, physical activity, and prior supplement use), study design (e.g., recruitment procedures, inclusion/exclusion criteria, followup, and population adherence), and intervention characteristics (e.g., supplements, chemical form, dose, frequency, duration of use, and timing of use), as well as health outcomes.

We abstracted health outcomes that included the number of participants experiencing an event and incidence rates. For cancer outcomes, we abstracted any data on solid or hematologic malignancies and related deaths; we did not abstract data on precancerous lesions (e.g., cervical intraepithelial neoplasia). For cardiovascular health outcomes, we abstracted any CVD (e.g., coronary heart disease, ischemic heart disease, coronary artery disease, atherosclerotic heart disease, atherosclerosis, and diabetes), cardiomyopathy, angina pectoris (i.e., chest pain), MI, stroke (both ischemic and hemorrhagic and cerebrovascular accidents), heart failure, and related deaths. We did not abstract cardiovascular symptoms, such as palpitations and arrhythmias, or risk factors (e.g., blood pressure, lipid levels). For all-cause mortality, we abstracted all-cause mortality rates. For adverse events, as mentioned previously, we abstracted only those events that were reported in more than 5 percent of participants, if there was a significant difference among the interventions groups, and if they were serious adverse events as defined by the study.

## Data Synthesis and Analysis

We synthesized the results of the included studies of the four KQs in related pairs (i.e., KQs 1 and 2 for multivitamin supplements, KQs 3 and 4 for single and paired supplements). For KQs 3 and 4, the results are grouped by single supplement: beta-carotene, vitamin E, selenium, vitamin A, vitamin C, folic acid, vitamin D, and calcium. Paired or combination supplements are discussed under each individual supplement (e.g., beta-carotene in combination with vitamin A is discussed under two sections: beta-carotene and vitamin A), as included studies reported minimal interaction effects with combination supplements. Vitamin D and calcium combination supplements were discussed separately from calcium alone and vitamin D alone.

We created summary evidence tables for each supplement showing the main outcomes (i.e., CVD incidence, cancer incidence, mortality, and harms) along with important population characteristics and study design features. We critically examined the population characteristics and design features to identify the range of results and potential associations with heterogeneity of treatment effects across studies. Other study design and baseline demographics are provided in Appendix E.

For each supplement, we created results tables for CVD (CVD incidence and cardiovascular-related deaths), cancer (any, the four major site-specific cancers [lung, colorectal, prostate, breast], and cancer-related deaths), and all-cause mortality. Other cancers were briefly discussed if there were statistically significant differences between groups within a particular study or if there were differences across studies; otherwise, we indicated that there was no statistically significant effect on other cancers.

The results tables include the number of participants experiencing an event and study-reported relative risks (RRs), hazard ratios (HRs), odds ratios (ORs), confidence intervals (CIs), and p-values. Most studies reported adjusted outcome measures; therefore, we did not calculate unadjusted risk ratios. We examined the CIs and/or p-values to determine if an estimate reached statistical significance. We examined these estimates to determine if a supplement had a statistically significant effect on an outcome (beneficial or harmful) within a specific trial and across trials examining the same supplement. We noted any patterns across studies and explained any clinical heterogeneity across trials that might clarify any differences in results. None of the included studies adjusted the significance level for testing of multiple outcomes (e.g., overall cancer plus several site-specific cancers); we focused on the main outcomes of the trials (all CVD, all cancer, all-cause mortality), limiting the impact of multiple testing. We include data on the components of these main outcomes, but the statistical comparisons should not be interpreted as hypothesis tests.

Eight of the included RCTs used factorial designs (usually 2×2, but also including more arms). These studies appropriately report the results for each arm as designed, thus comparing all participants who received one of the interventions with all those who did not, ignoring the assignments to the other intervention in the two groups. Analysis of factorial studies should include a formal test for interaction between the components, since if such interaction is present, the main effects cannot be interpreted and analysis should be conducted for the separate arms. Most of the factorial studies did provide a test for interaction between the interventions and found none, although the power of the studies to detect an interaction was not presented. Two studies did report comparisons across individual cells, generally the cell receiving only one supplement with the cell receiving only placebo. We ignored these analyses in the synthesis since they are essentially post hoc and are not fully valid in the absence of an interaction. Furthermore, these analyses did not produce different results from the factorial analyses. The results by individual arm for these studies are provided in Appendix F Tables 1–6, Appendix F Figures 1 and 2.

We found few trials examining the use of a multivitamin supplement in the prevention of CVD and cancer; three RCTs addressed KQ 1 (benefits of multivitamin supplement use) and five studies addressed KQ 2 (harms of multivitamin supplement use). We identified a substantial body of evidence addressing the benefits (KQ 3) and harms (KQ 4) of single or functionally related pairs; there were very few trials included per supplement. We examined the evidence qualitatively and, when appropriate, quantitatively. We conducted meta-analyses to estimate the effect size of supplementation on CVD incidence, cancer incidence, and all-cause mortality for the longest followup time point (Figures 2–4). Additional forest plots for site-specific cancers (lung, colorectal, prostate, and breast only), MI, strokes, and CVD-related and cancer-related deaths are available in Appendix G Figures 1–12.

Figure 2 Relative Risk for Any Cardiovascular Disease Incidence at Longest Followup Only, by Supplement

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SUVIMAX = Supplementation in VItamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Figure 2 is a forest plot depicting the relative risk for any cardiovascular disease incidence at the longest followup, by supplement. This figure is discussed in the Results section.

Figure 3 Relative Risk for Any Cancer Incidence at Longest Followup Only, by Supplement

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SUVIMAX = Supplementation in VItamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Figure 3 is a forest plot depicting the relative risk for any cancer incidence at the longest followup, by supplement. This figure is discussed in the Results section.

Figure 4 Relative Risk for All-Cause Mortality at Longest Followup Only, by Supplement

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; ASAP = Antioxidant Supplementations in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; NSCPS = Nambour Skin Cancer Prevention Study; PHS = Physician's Health Study; REACT = Roche European American Cataract Trial; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SKICAP-AK = Skin Cancer Prevention Trial-Actinic Keratoses; SUVIMAX = Supplementation in VItamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Figure 4 is a forest plot depicting the relative risk for all-cause mortality at the longest followup, by supplement. This figure is discussed in the Results section.

We used Stata 11.2 (StataCorp LP, College State, TX) for all meta-analyses, entering the number of events and nonevents using the metan procedure.46 Since most of the included outcomes were relatively rare, to avoid bias associated with rare events we used either Peto's OR method (when events typically occurred in <1% of participants) or a fixed effects risk ratio model using the Mantel-Haenszel method (when events typically occurred in 1% to 10% of participants).47 When events were more common (>10% of participants), we conducted random effects analyses of risk ratios using the DerSimonian and Laird method.48 We examined the I^2^ statistic as a measure of statistical heterogeneity. We had too few trials to examine funnel plots for small-study effects. For most supplements, however, there were too few studies reporting similar outcomes in similar individuals for the pooled data to be interpretable; thus, for most supplements, the pooled analysis serves mainly to illustrate the results across the available trials that are discussed qualitatively. The overall pooled, unadjusted RR should not be overinterpreted due to the aforementioned clinical heterogeneity. In addition, the results from our meta-analysis may differ from those reported in original trials, as we used raw data and calculated unadjusted RRs and ORs. Throughout the report, we reference adjusted RRs, HRs, and ORs as reported in trials, unless we discuss pooled results.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the work of the USPSTF. We consulted with four USPSTF liaisons at key points in the review, particularly in the development of the KQs, analytic framework, and the inclusion and exclusion criteria, as well as finalizing the evidence synthesis. An AHRQ Medical Officer provided oversight of the project, reviewed the draft report, and assisted in the external review of the report. AHRQ had no role in the study selection, quality assessment, or evidence synthesis.