# Sensitivity Analysis: Random vs. Fixed Effects Models

Appendix H Table 1 Unadjusted Relative Risk for All-Cause Mortality at Longest Followup Only, by Supplement

Supplement | Study | DerSimonian and Laird Random Effects Unadjusted RR (95% CI) | Mantel-Haenszel Fixed Effects Unadjusted RR (95% CI)
MVI | REACT | 2.98 (0.82, 10.79) | 2.98 (0.82, 10.79)
MVI | PHS-II | 0.95 (0.89, 1.02) | 0.95 (0.89, 1.02)
MVI | SU.VI.MAX | 0.88 (0.71, 1.09) | 0.88 (0.71, 1.09)
MVI | Subtotal | 0.95 (0.80, 1.11) | 0.95 (0.89, 1.01)
Beta-carotene | WHS | 1.07 (0.74, 1.55) | 1.07 (0.74, 1.55)
Beta-carotene | NSCPS | 0.51 (0.25, 1.05) | 0.51 (0.25, 1.05)
Beta-carotene | SCPS | 1.03 (0.83, 1.27) | 1.03 (0.83, 1.27)
Beta-carotene | PHS-I | 1.01 (0.93, 1.10) | 1.01 (0.93, 1.10)
Beta-carotene | ATBC | 1.05 (1.02, 1.09) | 1.05 (1.02, 1.09)
Beta-carotene | Subtotal | 1.04 (0.99, 1.09) | 1.05 (1.02, 1.08)
Vitamin E | ASAP | 3.00 (0.32, 28.47) | 3.00 (0.32, 28.47)
Vitamin E | PHS-II | 1.03 (0.94, 1.12) | 1.03 (0.94, 1.12)
Vitamin E | WHS | 1.03 (0.93, 1.15) | 1.03 (0.93, 1.15)
Vitamin E | SELECT | 1.01 (0.90, 1.13) | 1.01 (0.90, 1.13)
Vitamin E | ATBC | 1.01 (0.98, 1.04) | 1.01 (0.98, 1.04)
Vitamin E | Subtotal | 1.01 (0.98, 1.04) | 1.01 (0.98, 1.04)
Selenium | NPC | 0.99 (0.78, 1.25) | 0.98 (0.78, 1.24)
Selenium | SELECT | 0.97 (0.87, 1.09) | 0.97 (0.87, 1.09)
Selenium | Subtotal | 0.97 (0.88, 1.08) | 0.97 (0.88, 1.08)
Vitamin A | SKICAP-AK | 1.15 (0.81, 1.65) | 1.15 (0.81, 1.65)
Vitamin C | ASAP | 1.00 (0.06, 15.82) | 1.00 (0.06, 15.82)
Vitamin C | PHS-II | 1.06 (0.97, 1.16) | 1.06 (0.97, 1.16)
Vitamin C | Subtotal | 1.06 (0.97, 1.16) | 1.06 (0.97, 1.16)
Folic Acid | AFPPS | 0.52 (0.24, 1.10) | 0.52 (0.24, 1.10)
Vitamin D | Trivedi 2003 | 0.90 (0.77, 1.07) | 0.90 (0.77, 1.07)
Vitamin D | RECORD | 0.95 (0.88, 1.02) | 0.95 (0.88, 1.02)
Vitamin D | Subtotal | 0.94 (0.88, 1.01) | 0.94 (0.87, 1.01)
Calcium | CPPS | 1.14 (0.65, 1.99) | 1.14 (0.65, 1.99)
Calcium | ACS | 1.18 (0.73, 1.92) | 1.18 (0.73, 1.92)
Calcium | RECORD | 1.03 (0.95, 1.11) | 1.03 (0.95, 1.11)
Calcium | Subtotal | 1.04 (0.96, 1.12) | 1.04 (0.96, 1.12)
Vitamin D + Calcium | WHI | 0.92 (0.83, 1.01) | 0.92 (0.83, 1.01)

Abbreviations: ACS = Auckland Calcium Study; AFPPS = Aspirin/Folate Polyp Prevention Study; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; NSCPS = Nambour Skin Cancer Prevention Study; PHS = Physician's Health Study; REACT = Roche European American Cataract Trial; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SKICAP-AK = Skin Cancer Prevention Trial-Actinic Keratoses; SU.VI.MAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix H Table 2 Unadjusted Relative Risk for Any Cancer Incidence at Longest Followup Only, by Supplement

Supplement | Study | DerSimonian and Laird Random Effects Unadjusted RR (95% CI) | Mantel-Haenszel Fixed Effects Unadjusted RR (95% CI)
MVI | PHS-II | 0.94 (0.87, 1.00) | 0.94 (0.87, 1.00)
MVI | SU.VI.MAX | 0.97 (0.86, 1.09) | 0.97 (0.86, 1.09)
MVI | Subtotal | 0.94 (0.89, 1.00) | 0.94 (0.89, 1.00)
Beta-carotene | WHS | 1.02 (0.89, 1.18) | 1.02 (0.89, 1.18)
Beta-carotene | PHS-I | 0.97 (0.90, 1.04) | 0.97 (0.90, 1.04)
Beta-carotene | Subtotal | 0.98 (0.92, 1.05) | 0.98 (0.92, 1.05)
Vitamin E | PHS-II | 1.03 (0.95, 1.12) | 1.03 (0.95, 1.12)
Vitamin E | WHS | 1.01 (0.94, 1.08) | 1.01 (0.94, 1.08)
Vitamin E | SELECT | 1.07 (0.99, 1.15) | 1.07 (0.99, 1.15)
Vitamin E | Subtotal | 1.03 (0.99, 1.08) | 1.03 (0.99, 1.08)
Selenium | NPC | 0.78 (0.62, 0.98) | 0.78 (0.62, 0.98)
Selenium | SELECT | 1.02 (0.94, 1.10) | 1.02 (0.94, 1.10)
Selenium | Subtotal | 0.91 (0.70, 1.18) | 0.99 (0.92, 1.06)
Vitamin C | PHS-II | 1.00 (0.92, 1.09) | 1.00 (0.92, 1.09)
Folic Acid | AFPPS | 1.65 (1.09, 2.51) | 1.65 (1.09, 2.51)
Vitamin D | Trivedi 2003 | 1.08 (0.89, 1.31) | 1.08 (0.89, 1.31)
Vitamin D | RECORD | 1.04 (0.91, 1.19) | 1.04 (0.91, 1.19)
Vitamin D | Subtotal | 1.05 (0.94, 1.18) | 1.05 (0.94, 1.18)
Calcium | CPPS | 0.72 (0.97, 1.37) | 0.72 (0.97, 1.37)
Calcium | Lappe 2007 | 0.55 (0.29, 1.03) | 0.55 (0.29, 1.03)
Calcium | RECORD | 1.08 (0.94, 1.23) | 1.08 (0.94, 1.23)
Calcium | Subtotal | 1.03 (0.90, 1.17) | 1.03 (0.90, 1.17)
Vitamin D + Calcium | WHI | 0.98 (0.92, 1.05) | 0.98 (0.92, 1.05)
Vitamin D + Calcium | Lappe 2007 | 0.42 (0.21, 0.83) | 0.42 (0.21, 0.83)
Vitamin D + Calcium | Subtotal | 0.69 (0.30, 1.57) | 0.98 (0.91, 1.04)

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SU.VI.MAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.