# Additional Meta-Analysis Figures

Appendix G Figure 1 Relative Risk for Cardiovascular Disease-Related Mortality at Longest Followup Only, by Supplement

Abbreviations: ACS = Auckland Calcium Study; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; NSCPS = Nambour Skin Cancer Prevention Study; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 1 is a forest plot depicting the relative risk for cardiovascular disease mortality at longest followup, by supplement, using data from the original randomized arms of the RECORD trial. This figure is discussed in the Methods and Results sections.

Appendix G Figure 2 Relative Risk for Myocardial Infarction at Longest Followup Only, by Supplement

Abbreviations: ACS = Auckland Calcium Study; AFPPS = Aspirin/Folate Polyp Prevention Study; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 2 is a forest plot depicting the relative risk for myocardial infarction at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 3 Relative Risk for Stroke at Longest Followup Only, by Supplement

Abbreviations: ACS = Auckland Calcium Study; AFPPS = Aspirin/Folate Polyp Prevention Study; CG = control group; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 3 is a forest plot depicting the relative risk for stroke at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 4 Relative Risk for Any Cancer-Related Mortality at Longest Followup Only, by Supplement

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; NSCPS = Nambour Skin Cancer Prevention Study; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 4 is a forest plot depicting the relative risk for any cancer-related mortality at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 5 Relative Risk for Lung Cancer at Longest Followup Only, by Supplement

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study.

Appendix G Figure 5 is a forest plot depicting the relative risk for lung cancer at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 6 Odds Ratio for Lung Cancer Mortality at Longest Followup Only, by Supplement

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; OR = odds ratio; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHS = Women's Health Study.

Appendix G Figure 6 is a forest plot depicting the odds ratio for lung cancer mortality at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 7 Odds Ratio for Colorectal Cancer at Longest Followup Only, by Supplement

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; OR = odds ratio; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 7 is a forest plot depicting the odds ratio for colorectal cancer at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 8 Odds Ratio for Colorectal Cancer Mortality at Longest Followup Only, by Supplement

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; OR = odds ratio; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; SELECT = Selenium and Vitamin E Cancer Prevention Trial; WHI = Women's Health Initiative.

Appendix G Figure 8 is a forest plot depicting the odds ratio for colorectal cancer mortality at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 9 Relative Risk for Prostate Cancer at Longest Followup Only, by Supplement

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CARET = Carotene and Retinol Efficacy Trial; CG = control group; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SUVIMAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative.

Appendix G Figure 9 is a forest plot depicting the relative risk for prostate cancer at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 10 Odds Ratio for Prostate Cancer Mortality at Longest Followup Only, by Supplement

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; OR = odds ratio; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

Appendix G Figure 10 is a forest plot depicting the odds ratio for prostate cancer mortality at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 11 Relative Risk for Breast Cancer at Longest Followup Only, by Supplement

Abbreviations: CARET = Carotene and Retinol Efficacy Trial; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SUVIMAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix G Figure 11 is a forest plot depicting the relative risk for breast cancer at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.

Appendix G Figure 12 Odds Ratio for Breast Cancer Mortality at Longest Followup Only, by Supplement

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; OR = odds ratio; RECORD = Randomized Evaluation of Calcium or Vitamin D; WHI = Women's Health Initiative.

Appendix G Figure 12 is a forest plot depicting the odds ratio for breast cancer mortality at longest followup, by supplement. The results of this forest plot are not discussed in the Results section and are included for informational purposes only.