# Outcomes Reported by Original Randomized Arms Among the 2×2 Factorial-Designed Randomized, Controlled Trials

Appendix F Table 1 Cancer Incidence, Cancer Mortality, and All-Cause Mortality Among Beta-Carotene Alone vs. Placebo Arms of ATBC Trial73,76,77

Outcome | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR | 95% CI | P-value
Lung cancer^*^ | 8 | 242/7,282 (3.3) | 209/7,287 (2.9) | 1.16 | 0.97 to 1.40 | NR
Lung cancer^*^ | 11 | 140/6,281 (2.2) | 120/6,375 (1.9) | 1.19 | 0.93 to 1.52 | NR
Lung cancer^*^ | 14 | 120/5,625 (2.1) | 130/5,782 (2.2) | 0.97 | 0.76 to 1.25 | NR
Prostate cancer^*,†^ | 6.1 | 80/7,282 (1.1) | 67/7,287 (0.9) | 1.20 | 0.87 to 1.66 | NR
Prostate cancer^*,†^ | 8 | 82/7,282 (1.1) | 67/7,287 (0.9) | 1.23 | 0.89 to 1.70 | NR
Prostate cancer^*,†^ | 11 | 73/6,306 (1.2) | 74/6,388 (1.2) | 1.00 | 0.73 to 1.39 | NR
Prostate cancer^*,†^ | 14 | 106/5,615 (1.9) | 104/5,745 (1.8) | 1.05 | 0.80 to 1.38 | NR
Colorectal cancer^*,†,‡^ | 6.1 | 39/7,282 (0.5) | 37/7,287 (0.5) | 1.06 | 0.68 to 1.66 | NR
Colorectal cancer^*,†,‡^ | 8 | 39/7,282 (0.5) | 37/7,287 (0.5) | 1.06 | 0.67 to 1.66 | NR
Colorectal cancer^*,†,‡^ | 11 | 22/6,340 (0.3) | 20/6,416 (0.3) | 1.12 | 0.61 to 2.05 | NR
Colorectal cancer^*,†,‡^ | 14 | 38/5,677 (0.7) | 18/5,806 (0.3) | 2.18 | 1.25 to 3.82 | NR
Colorectal cancer death | 6.1 | 13/7,282 (0.2) | 11/7,287 (0.2) | NR | NR | NR
Prostate cancer death | 6.1 | 21/7,282 (0.3) | 18/7,287 (0.2) | NR | NR | NR
All-cause mortality | 8 | 919/7,282 (12.6) | 851/7,287 (11.7) | 1.08 | 0.99 to 1.19 | NR
All-cause mortality | 11 | 651/6,363 (10.2) | 598/6,436 (9.3) | 1.11 | 0.99 to 1.24 | NR
All-cause mortality | 14 | 728/5,712 (12.7) | 668/5,838 (11.4) | 1.12 | 1.01 to 1.25 | NR
All-cause mortality | 16 | 495/4,984 (9.9) | 488/5,170 (9.4) | 1.06 | 0.93 to 1.20 | NR

* Overall 6-year posttrial followup: lung cancer RR, 1.06 (95% CI, 0.94 to 1.20); prostate cancer RR 1.06 (95% CI, 0.91 to 1.23), colorectal cancer RR, 1.44 (95% CI, 1.09 to 1.90).

† Subsequent ATBC publications after the initial publication59 reclassified cancer cases: three additional prostate cancer cases were identified and seven were reclassified as nonmalignant; colorectal cancer cases excluded six participants with carcinoids and squamous cell carcinoma of the anal canal, an additional eight colorectal cancer cases were reclassified based on pathology.

‡ Combined colon and rectal cancer cases.

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; NR = not reported; RR = relative risk; y = years.

Appendix F Table 2 Cancer Incidence, Cancer Mortality, and All-Cause Mortality Among Vitamin E Alone vs. Placebo Arms of the ATBC Trial73,76,77

Outcome | Mean followup (y) | Intervention, # of subjects with events (%) | Comparator, # of subjects with events (%) | RR | 95% CI | P-value
Lung cancer | 11 | 205/7,286 (2.8) | 209/7,287 (2.9) | 0.98 | 0.81 to 1.19 | NR
Lung cancer | 14 | 112/6,349 (1.8) | 120/6,375 (1.9) | 0.94 | 0.73 to 1.21 | NR
Lung cancer | 16 | 147/5,780 (2.5) | 130/5,782 (2.2) | 1.14 | 0.90 to 1.44 | NR
Prostate cancer | 6.1–11 | 43/7,286 (0.6) | 67/7,287 (0.9) | 0.64 | 0.44 to 0.94 | NR
Prostate cancer | 14 | 54/6,349 (0.9) | 74/6,375 (1.2) | 0.73 | 0.51 to 1.04 | NR
Prostate cancer | 16 | 98/5,780 (1.7) | 104/5,782 (1.8) | 0.94 | 0.72 to 1.24 | NR
Colorectal cancer | 6.1 | 29/7,286 (0.4) | 37/7,287 (0.5) | 0.79 | 0.48 to 1.28 | NR
Colorectal cancer | 11 | 29/7,286 (0.4) | 37/7,287 (0.5) | 0.78 | 0.48 to 1.28 | NR
Colorectal cancer | 14 | 25/6,349 (0.4) | 20/6,375 (0.3) | 1.25 | 0.70 to 2.26 | NR
Colorectal cancer | 16 | 22/5,780 (0.4) | 18/5,782 (0.3) | 1.23 | 0.66 to 2.29 | NR
Prostate cancer death | 11 | 11/7,286 (0.2) | 18/7,287 (0.2) | NR | NR | NR
Colorectal cancer death | 6.1 | 12/7,286 (0.2) | 11/7,287 (0.2) | NR | NR | NR
All-cause mortality | 8 | 868/7,286 (11.9) | 851/7,287 (11.7) | 1.02 | 0.93 to 1.12 | NR
All-cause mortality | 11 | 566/6,349 (8.9) | 598/6,375 (9.4) | 0.95 | 0.85 to 1.07 | NR
All-cause mortality | 14 | 733/5,780 (12.7) | 668/5,782 (11.6) | 1.10 | 0.99 to 1.23 | NR
All-cause mortality | 16 | 504/5,119 (9.8) | 488/5,170 (9.4) | 1.05 | 0.93 to 1.19 | NR

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; NR = not reported; RR = relative risk.

Appendix F Table 3 Cancer Incidence, Cancer Mortality, and All-Cause Mortality Among Beta-Carotene Combined With Vitamin E vs. Placebo Arms of the ATBC Trial73,76,77

Outcome | Mean followup (m) | Intervention, # of subjects (%) | Comparator, # of subjects (%) | RR^†^ | 95% CI | P-value
Lung cancer | 96 | 239/7,278 (3.3) | 209/7,287 (2.9) | 1.15 | 0.96 to 1.38 | NR
Lung cancer | 132^*^ | 126/6,278 (2) | 120/6,375 (1.9) | 1.07 | 0.83 to 1.38 | NR
Lung cancer | 168^*^ | 140/5,651 (2.5) | 130/5,782 (2.2) | 1.11 | 0.87 to 1.41 | NR
Prostate cancer | 73.2 | 56/7,278 (0.8) | 67/7,287 (0.9) | 1.23^‡^ | 0.96 to 1.58 | 0.088
Prostate cancer | 96 | 56/7,278 (0.8) | 67/7,287 (0.9) | 0.84 | 0.59 to 1.20 | NR
Prostate cancer | 132^*^ | 76/6,308 (1.2) | 74/6,388 (1.2) | 1.05 | 0.76 to 1.44 | NR
Prostate cancer | 168^*^ | 87/5,622(1.5) | 104/5,745 (1.8) | 0.86 | 0.65 to 1.15 | NR
Colorectal cancer | 73.2 | 30/7,278 (0.4) | 37/7,287 (0.5) | 0.82 | 0.50 to 1.32 | NR
Colorectal cancer | 96 | 30/7,278 (0.4) | 37/7,287 (0.5) | 0.81 | 0.50 to 1.32 | NR
Colorectal cancer | 132^*^ | 25/6,330 (0.4) | 20/6,416 (0.3) | 1.27 | 0.71 to 2.29 | NR
Colorectal cancer | 168^*^ | 35/5,696 (0.6) | 18/5,806 (0.3) | 2.00 | 1.13 to 3.54 | NR
Prostate cancer death | 73.2 | 12/7,278 (0.2) | 18/7,287 (0.2) | NR | NR | NR
Colorectal cancer death | 73.2 | 10/7,278 (0.1) | 11/7,287 (0.2) | NR | NR | NR
All-cause mortality | 96 | 932/7,278 (12.8) | 851/7,287 (11.7) | 1.10 | 1.00 to 1.21 | NR
All-cause mortality | 132^*^ | 627/6,346 (9.9) | 598/6,436 (9.3) | 1.07 | 0.96 to 1.20 | NR
All-cause mortality | 168^*^ | 727/5,719 (12.7) | 668/5,838 (11.4) | 1.12 | 1.01 to 1.25 | NR
All-cause mortality | 192^*^ | 476/4,992 (9.5) | 488/5,170 (9.4) | 1.01 | 0.89 to 1.15 | NR

* Posttrial followup 3 and 6 years after end of intervention.

† Crude RR reported unless otherwise specified.

‡ Adjusted for age, number of cigarettes, years of smoking, and fat intake.

Abbreviations: ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; m = month; NR = not reported; RR = relative risk.

Appendix F Table 4 Cardiovascular Disease and Cancer Incidence, Mortality, and All-Cause Mortality Among Vitamin D Alone vs. Placebo Arms of the RECORD Trial103

Outcome | Mean followup (y) | Intervention, # of subjects (%) | Comparator, # of subjects (%) | RR | 95% CI | P-value
Any CVD death | 6.2 | 173/1,343 (12.9) | 182/1,332 (13.7) | NR | NR | NR
Fatal CHD | 6.2 | 74/1,343 (5.5) | 85/1,332 (6.4) | NR | NR | NR
Fatal stroke | 6.2 | 59/1,343 (4.4) | 51/1,332 (3.8) | NR | NR | NR
Any cancer | 6.2 | 187/1,343 (13.9) | 165/1,332 (12.4) | NR | NR | NR
Breast cancer | 6.2 | 23/1,343 (1.7) | 16/1,332 (1.2) | NR | NR | NR
Colorectal cancer | 6.2 | 17/1,343 (1.3) | 8/1,332 (0.6) | NR | NR | NR
Lung cancer | 6.2 | 14/1,343 (1.0) | 18/1,332 (1.4) | NR | NR | NR
Prostate cancer | 6.2 | 9/1,343 (0.7) | 8/1,332 (0.6) | NR | NR | NR
Any cancer death | 6.2 | 73/1,343 (5.4) | 78/1,332 (5.9) | NR | NR | NR
Breast cancer death | 6.2 | 7/1,343 (0.5) | 4/1,332 (0.3) | NR | NR | NR
Colorectal cancer death | 6.2 | 7/1,343 (0.5) | 6/1,332 (0.5) | NR | NR | NR
Lung cancer death | 6.2 | 10/1,343 (0.7) | 21/1,332 (1.6) | NR | NR | NR
All-cause mortality | 6.2 | 421/1,343 (31.3) | 434/1,332 (32.6) | NR | NR | NR

Abbreviations: CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

Appendix F Table 5 Cardiovascular Disease and Cancer Incidence, Mortality, and All-Cause Mortality Among Calcium Alone vs. Placebo Arms of the RECORD Trial103

Outcome | Mean followup ( y) | Intervention, # of subjects (%) | Comparator, # of subjects (%) | RR | 95% CI | P-value
Any CVD death | 6.2 | 194/1,311 (14.8) | 182/1,332 (13.7) | NR | NR | NR
Fatal stroke | 6.2 | 54/1,311 (4.1) | 51/1,332 (3.8) | NR | NR | NR
Fatal vascular disease | 6.2 | 91/1,311 (6.9) | 85/1,332 (6.4) | NR | NR | NR
Any cancer | 6.2 | 189/1,311 (14.4) | 165/1,332 (12.4) | NR | NR | NR
Breast cancer | 6.2 | 21/1,311 (1.6) | 16/1,332 (1.2) | NR | NR | NR
Colorectal cancer | 6.2 | 22/1,311 (1.7) | 8/1,332 (0.6) | NR | NR | NR
Lung cancer | 6.2 | 14/1,311 (1.1) | 18/1,332 (1.3) | NR | NR | NR
Prostate cancer | 6.2 | 4/1,311 (0.3) | 8/1,332 (0.6) | NR | NR | NR
Any cancer death | 6.2 | 95/1,311 (7.2) | 78/1,332 (5.9) | NR | NR | NR
Breast cancer death | 6.2 | 9/1,311 (.6) | 4/1,332 (.3) | NR | NR | NR
Colorectal cancer death | 6.2 | 7/1,311 (0.5) | 6/1,332 (0.5) | NR | NR | NR
Lung cancer death | 6.2 | 13/1,311 (1) | 21/1,332 (1.6) | NR | NR | NR
Prostate cancer death | 6.2 | 3/1,311 (0.2) | 3/1,332 (0.2) | NR | NR | NR
All-cause mortality | 6.2 | 447/1,311 (34.1) | 434/1,332 (32.6) | NR | NR | NR

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

Appendix F Table 6 Cardiovascular Disease and Cancer Incidence, Mortality, and All-Cause Mortality Among Vitamin D Combined With Calcium vs. Placebo Arms of the RECORD Trial103

Outcome | Mean followup (y) | Intervention, # of subjects (%) | Comparator, # of subjects (%) | RR | 95% CI | P-value
Any CVD death | 6.2 | 177/1,306 (13.6) | 182/1,332 (13.6) | NR | NR | NR
Fatal stroke | 6.2 | 56/1,306 (4.3) | 51/1,332 (3.8) | NR | NR | NR
Fatal CHD | 6.2 | 88/1,306 (6.7) | 85/1,332 (6.4) | NR | NR | NR
Any cancer | 6.2 | 182/1,306 (13.9) | 165/1,332 (12.4) | NR | NR | NR
Breast cancer | 6.2 | 20/1,306 (1.5) | 16/1,332 (1.2) | NR | NR | NR
Colorectal cancer | 6.2 | 24/1,306 (1.8) | 8/1,332 (0.6) | NR | NR | NR
Lung cancer | 6.2 | 10/1,306 (0.8) | 18/1,332 (1.4) | NR | NR | NR
Prostate cancer | 6.2 | 8/1,306 (0.6) | 17/1,332 (1.3) | NR | NR | NR
Any cancer death | 6.2 | 83/1,306 (6.4) | 78/1,332 (5.9) | NR | NR | NR
Breast cancer death | 6.2 | 7/1,306 (0.5) | 4/1,332 (0.3) | NR | NR | NR
Colorectal cancer death | 6.2 | 13/1,306 (1.0) | 6/1,332 (0.5) | NR | NR | NR
Lung cancer death | 6.2 | 14/1,306 (1.1) | 21/1,332 (1.6) | NR | NR | NR
Prostate cancer death | 6.2 | 2/1,306 (0.2) | 3/1,332 (0.2) | NR | NR | NR
All-cause mortality | 6.2 | 415/1,306 (31.8) | 434/1,336 (32.5) | NR | NR | NR

Abbreviations: CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; NR = not reported; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; y = years.

Appendix F Figure 1 Relative Risk for Any Cancer Incidence at Longest Followup Only, by Supplement, Original Randomized Arms of the RECORD Trial

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; CG = control group; CI = confidence interval; IG = intervention group; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; PHS = Physician's Health Study; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SU.VI.MAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix F Figure 1 is a forest plot depicting the relative risk for any cancer incidence at longest followup, by supplement, using data from the original randomized arms of the RECORD trial. This figure is discussed in the Methods and Results sections.

Appendix F Figure 2 Relative Risk for All-Cause Mortality at Longest Followup Only, by Supplement, Original Randomized Arms of the RECORD Trial

Abbreviations: ACS = Auckland Calcium Study; AFPPS = Aspirin/Folate Polyp Prevention Study; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta-Carotene Cancer Prevention; CI = confidence interval; CPPS = Calcium Polyp Prevention Study; MVI = multivitamin; NPC = Nutritional Prevention of Cancer; NSCPS = Nambour Skin Cancer Prevention Study; PHS = Physician's Health Study; REACT = Roche European American Cataract Trial; RECORD = Randomized Evaluation of Calcium or Vitamin D; RR = relative risk; SCPS = Skin Cancer Prevention Study; SELECT = Selenium and Vitamin E Cancer Prevention Trial; SKICAP-AK = Skin Cancer Prevention Trial-Actinic Keratoses; SU.VI.MAX = Supplementation in Vitamins and Mineral Antioxidants Study; WHI = Women's Health Initiative; WHS = Women's Health Study.

Appendix F Figure 2 is a forest plot depicting the relative risk for all-cause mortality at longest followup, by supplement, using data from the original randomized arms of the RECORD trial. This figure is discussed in the Methods and Results sections.