# Evidence Tables

Appendix E Table 1 Study Characteristics of Included Studies

Appendix E Table 2 Baseline Demographics of Included Studies (Entire Study Population)