# Excluded Studies

Exclusion code
E1. Study not relevant
E2. Wrong setting
E3. Wrong population
E4. Study quality
E5. Wrong study design
E6. No relevant outcomes
E7. Precedes search period
E8. Published in a non-English language
E9. Used as a source document only
E10. Observational study reporting harms on cardiovascular disease, cancer or mortality
E11. High-dose intervention (greater than the upper tolerable limit set by the Food Nutrition Board)

1 Agler AH, Kurth T, Gaziano JM, et al. Randomised vitamin E supplementation and risk of chronic lung disease in the Women's Health Study. Thorax. 2011;66(4):320-5. KQ3E6, KQ4E6. [pmid: 21257986].
2 Albert CM, Cook NR, Gaziano JM, et al. Effect of folic acid and B vitamins on risk of cardiovascular events and total mortality among women at high risk for cardiovascular disease: a randomized trial. JAMA. May. 7. 2008;299(17):2027-36. KQ3E3. [pmid: 18460663].
3 Aldosary BM, Sutter ME, Schwartz M, et al. Case series of selenium toxicity from a nutritional supplement. Clinical Toxicology: The Official Journal of the American Academy of Clinical Toxicology & European Association of Poisons Centres & Clinical Toxicologists. Jan. 2012;50(1):57-64. KQ4E1. [pmid: 22165838].
4 Algotar AM, Stratton MS, Ahmann FR, et al. Phase 3 clinical trial investigating the effect of selenium supplementation in men at high-risk for prostate cancer. Prostate. Feb. 15. 2013;73(3):328-35. KQ3E4, KQ4E4. [pmid: 22887343].
5 Alkhenizan A, Hafez K. The role of vitamin E in the prevention of cancer: a meta-analysis of randomized controlled trials. Ann Saudi Med. Nov. 2007;27(6):409-14. KQ3E9. [pmid: 18059122].
6 Altaweel MM, Hanzlik RP, Ver Hoeve JN, et al. Ocular and systemic safety evaluation of calcium formate as a dietary supplement. J Ocul Pharmacol Ther. Jun. 2009;25(3):223-30. KQ4E1. [pmid: 19456257].
7 Anderson LN, Cotterchio M, Vieth R, et al. Vitamin D and calcium intakes and breast cancer risk in pre- and postmenopausal women. Am J Clin Nutr. Jun. 2010;91(6):1699-707. KQ3E5, KQ4E1. [pmid: 20392891].
8 Andreeva VA, Touvier M, Kesse-Guyot E, et al. B vitamin and/or omega-3 fatty acid supplementation and cancer: ancillary findings from the Supplementation with Folate, Vitamins B6 and B12, and/or Omega-3 fatty acids (SU.FOL.OM3) randomized trial. Arch Intern Med. Apr. 9. 2012;172(7):540-7. KQ3E5, KQ4E5. [pmid: 22331983].
9 Arain MA, Abdul QA. Systematic review on “vitamin E and prevention of colorectal cancer”. Pak J Pharma Sci. Apr. 2010;23(2):125-30. KQ3E4. [pmid: 20363687].
10 AREDS. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. Oct. 2001;119(10):1417-36. KQ2E11. [pmid: 11594942].
11 AREDS. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E and beta carotene for age-related cataract and vision loss: AREDS report no. 9. Arch Ophthalmol. Oct. 2001;119(10):1439-52. KQ1E6, KQ2E11. [pmid: 11594943].
12 Arem H, Weinstein SJ, Horst RL, et al. Serum 25-hydroxyvitamin D and risk of oropharynx and larynx cancers in finnish men. Cancer Epidemiol Biomarkers Prev. 2011;20(6):1178-84. KQ3E1, KQ4E1. [pmid: 21527582].
13 Asgari MM, Maruti SS, Kushi LH, et al. Antioxidant supplementation and risk of incident melanomas: results of a large prospective cohort study. Arch Dermatol. Aug. 2009;145(8):879-82. KQ3E5, KQ4E5. [pmid: 19687417].
14 Autier P, Gandini S. Vitamin D supplementation and total mortality: a meta-analysis of randomized controlled trials. Arch Intern Med. Sep. 10. 2007;167(16):1730-7. KQ3E9. [pmid: 17846391].
15 Avenell A, Campbell MK, Cook JA, et al. Effect of multivitamin and multimineral supplements on morbidity from infections in older people (MAVIS trial): pragmatic, randomised, double blind, placebo controlled trial. BMJ. Aug. 6. 2005;331(7512):324-9. KQ2E6. [pmid: 16081445].
16 Barengolts E. Vitamin D role and use in prediabetes. Endocr Pract. 2010;16(3):476-85. KQ3E4, KQ4E4. [pmid: 20150028].
17 Bays H, Shah A, Dong Q, et al. Extended-release niacin/laropiprant lipid-altering consistency across patient subgroups. Int J Clin Pract. Apr. 2011;65(4):436-45. KQ3E6. [pmid: 21401833].
18 Bazzano LA, Reynolds K, Holder KN, et al. Effect of folic acid supplementation on risk of cardiovascular diseases: a meta-analysis of randomized controlled trials. JAMA. Dec. 13. 2006;296(22):2720-6. KQ3E1. [pmid: 17164458].
19 Beletate V, El Dib RP, Atallah AN. Zinc supplementation for the prevention of type 2 diabetes mellitus. Cochrane Database Syst Rev. 2007;(1):CD005525. KQ3E6. [pmid: 17253560].
20 Bell SJ, Grochoski GT. How safe is vitamin E supplementation?. Crit Rev Food Sci Nutr. Sep. 2008;48(8):760-74. KQ4E5. [pmid: 18756398].
21 Bin Q, Hu X, Cao Y, et al. The role of vitamin E (tocopherol) supplementation in the prevention of stroke. A meta-analysis of 13 randomised controlled trials. Thromb Haemost. Apr. 2011;105(4):579-85. KQ3E9. [pmid: 21264448].
22 Bjelakovic G, Nikolova D, Simonetti RG, et al. Systematic review: primary and secondary prevention of gastrointestinal cancers with antioxidant supplements. Aliment Pharmacol Ther. Sep. 15. 2008;28(6):689-703. KQ3E9. [pmid: 19145725].
23 Bjelakovic G, Nikolova D, Simonetti RG, et al. Antioxidant supplements for preventing gastrointestinal cancers. Cochrane Database Syst Rev. 2008;(3):CD004183. KQ3E9. [pmid: 18677777].
24 Bjelakovic G, Nikolova D, Gluud LL, et al. Antioxidant supplements for prevention of mortality in healthy participants and patients with various diseases. Cochrane Database Syst Rev. 2008;(2):CD007176. KQ3E9. [pmid: 18425980].
25 Block JP. A meta-analysis raises concerns about the cardiovascular risks of calcium supplementation: Commentary. J Clin Outcomes Manage. 2011;18(1):8-10. PMID: None. KQ4E5.
26 Blot WJ, Li JY, Taylor PR, et al. Nutrition intervention trials in Linxian, China: supplementation with specific vitamin/mineral combinations, cancer incidence, and disease-specific mortality in the general population. J Natl Cancer Inst. Sep. 15. 1993;85(18):1483-92. KQ1E2, KQ3E2. [pmid: 8360931].
27 Blot WJ, Li JY, Taylor PR, et al. The Linxian trials: mortality rates by vitamin-mineral intervention group. Am J Clin Nutr. Dec. 1995;62(6 Suppl):1424S-6S. KQ1E2, KQ3E2. [pmid: 7495242].
28 Bolland MJ, Grey A, Gamble GD, et al. Risk of cardiovascular events with calcium/vitamin D: a reanalysis of the Women's Health Initiative. J Bone Miner Res. 2010;25:S50. PMID: None. KQ4E6.
29 Bolland MJ, Avenell A, Baron JA, et al. Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ. 2010;341:c3691. KQ3E9, KQ4E9. [pmid: 20671013].
30 Bolland MJ, Grey A, Reid IR. Calcium supplements and cardiovascular risk. Journal of Bone & Mineral Research. Apr. 2011;26(4):899-1. KQ3E9, KQ4E9. [pmid: 21433072].
31 Bolland MJ, Grey A, Gamble GD, et al. Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women's Health Initiative (WHI) limited-access data set. Am J Clin Nutr. Oct. 2011;94(4):1144-9. KQ4E6. [pmid: 21880848].
32 Bolland MJ, Grey A, Avenell A, et al. Calcium supplements with or without vitamin D and risk of cardiovascular events: reanalysis of the Women's Health Initiative limited access dataset and meta-analysis. BMJ. 2011;342:d2040. KQ4E6. [pmid: 21505219].
33 Brinkman MT, Karagas MR, Zens MS, et al. Minerals and vitamins and the risk of bladder cancer: results from the New Hampshire Study. Cancer Causes Control. Apr. 2010;21(4):609-19. KQ1E1, KQ2E1, KQ4E1. [pmid: 20043202].
34 Bruckert E, Labreuche J, Amarenco P. Meta-analysis of the effect of nicotinic acid alone or in combination on cardiovascular events and atherosclerosis. Atherosclerosis. Jun. 2010;210(2):353-61. KQ3E9. [pmid: 20079494].
35 Brunner RL, Wactawski-Wende J, Caan BJ, et al. The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women's Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutrition & Cancer. 2011;63(6):827-41. KQ4E6. [pmid: 21774589].
36 Buhr G, Bales CW. Nutritional supplements for older adults: review and recommendations--Part II. J Nutr Elder. Jan. 2010;29(1):42-71. KQ1E5, KQ3E5. [pmid: 20391042].
37 Buring JE, Hennekens C. The Women's Health Study: rationale and background. J Myocardial Ischemia. 1992;4(3):30-40. PMID: None. KQ3E6, KQ4E6.
38 Buring JE, Hennekens C. The Women's Health Study: summary of study design. J Myocardial Ischemia. 1992;4(3):27-9. PMID: None. KQ3E6, KQ4E6.
39 Carr DR, Trevino JJ, Donnelly HB. Retinoids for chemoprophylaxis of nonmelanoma skin cancer. Dermatol Surg. 2011;37(2):129-45. KQ3E5. [pmid: 21276130].
40 Carroll C, Cooper K, Papaioannou D, et al. Supplemental calcium in the chemoprevention of colorectal cancer: a systematic review and meta-analysis. Clin Ther. May. 2010;32(5):789-803. KQ3E9. [pmid: 20685491].
41 Carroll C, Cooper K, Papaioannou D, et al. Meta-analysis: folic acid in the chemoprevention of colorectal adenomas and colorectal cancer. Aliment Pharmacol Ther. 2010;31(7):708-18. KQ3E9. [pmid: 20085565].
42 Chacko SA, Song Y, Manson JE, et al. Serum 25-hydroxyvitamin D concentrations in relation to cardiometabolic risk factors and metabolic syndrome in postmenopausal women. Am J Clin Nutr. 2011;94(1):209-17. KQ3E1, KQ4E1. [pmid: 21613558].
43 Chae CU, Albert CM, Moorthy MV, et al. Vitamin E supplementation and the risk of heart failure in women. Circ Heart Fail. Mar. 1. 2012;5(2):176-82. KQ4E6. [pmid: 22438520].
44 Chan AL, Leung HW, Wang SF. Multivitamin supplement use and risk of breast cancer: a meta-analysis. Ann Pharmacother. Apr. 2011;45(4):476-84. KQ2E1, KQ3E1. [pmid: 21487086].
45 Chen P, Hu P, Xie D, et al. Meta-analysis of vitamin D, calcium and the prevention of breast cancer. Breast Cancer Res Treat. Jun. 2010;121(2):469-77. KQ3E1. [pmid: 19851861].
46 Chlebowski RT, Pettinger M, Kooperberg C. Caution in reinterpreting the Women's Health Initiative (WHI) calcium and vitamin D trial breast cancer results. Am J Clin Nutr. 2012;95(1):258-9. KQ3E6, KQ4E6. [pmid: 22189262].
47 Christen WG, Glynn RJ, Sesso HD, et al. Vitamins E and C and medical record-confirmed age-related macular degeneration in a randomized trial of male physicians. Ophthalmology. Aug. 2012;119(8):1642-9. KQ3E6, KQ4E6. [pmid: 22503302].
48 Chung M, Balk EM, Brendel M, et al. Vitamin D and calcium: a systematic review of health outcomes. AHRQ Publication No. 09-E015. Rockville, MD. Agency for Healthcare Research and Quality. 2009. [pmid: 20629479]. KQ3E9, KQ4E9.
49 Clark L, Krongrad A, Dalkin B, et al. Decreased incidence of prostate cancer with selenium supplementation: 1983-96 results of a double-blind cancer prevention trial. Eur J Cancer Prev. 1997;6(5):497-8. PMID: None. KQ3E9.
50 Clarke R, Lewington S, Sherliker P, et al. Effects of B-vitamins on plasma homocysteine concentrations and on risk of cardiovascular disease and dementia. Curr Opin Clin Nutr Metab Care. Jan. 2007;10(1):32-9. KQ3E3, KQ4E3. [pmid: 17143052].
51 Clarke R, Halsey J, Lewington S, et al. Effects of lowering homocysteine levels with B vitamins on cardiovascular disease, cancer, and cause-specific mortality: Meta-analysis of 8 randomized trials involving 37 485 individuals. Arch Intern Med. Oct. 11. 2010;170(18):1622-31. KQ3E3. [pmid: 20937919].
52 Clarke R, Halsey J, Bennett D, et al. Homocysteine and vascular disease: review of published results of the homocysteine-lowering trials. J Inherit Metab Dis. Feb. 2011;34(1):83-91. KQ3E3. [pmid: 21069462].
53 Cole BF, Baron JA, Sandler RS, et al. Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. Jun. 6. 2007;297(21):2351-9. KQ4E6. [pmid: 17551129].
54 Cook LS, Neilson HK, Lorenzetti DL, et al. A systematic literature review of vitamin D and ovarian cancer. Am J Obstet Gynecol. Jul. 2010;203(1):70-8. KQ3E1. [pmid: 20227054].
55 Cook NR, Le IM, Manson JE, et al. Effects of beta-carotene supplementation on cancer incidence by baseline characteristics in the Physicians' Health Study (United States). Cancer Causes Control. Aug. 2000;11(7):617-26. KQ4E6. [pmid: 10977106].
56 Cooper K, Squires H, Carroll C, et al. Chemoprevention of colorectal cancer: systematic review and economic evaluation. Health Technol Assess. Jun. 2010;14(32):1-206. KQ1E9, KQ3E9. [pmid: 20594533].
57 Coulter ID, Hardy ML, Morton SC, et al. Antioxidants vitamin C and vitamin e for the prevention and treatment of cancer. J Gen Intern Med. Jul. 2006;21(7):735-44. KQ3E9. [pmid: 16808775].
58 Cranney A, Horsley T, O'Donnell S, et al. Effectiveness and safety of vitamin D in relation to bone health. AHRQ Publication No. 07-E013. Rockville, MD. Agency for Healthcare Research and Quality. 2007. [pmid: 18088161]. KQ4E9.
59 Davey SG, Ebrahim S. Folate supplementation and cardiovascular disease. Lancet. Nov. 12. 2005;366(9498):1679-81. KQ3E5, KQ4E5. [pmid: 16291049].
60 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. Jan. 13. 2001;357(9250):89-95. KQ3E3. [pmid: 11197445].
61 Dennert G, Zwahlen M, Brinkman M, et al. Selenium for preventing cancer. Cochrane Database Syst Rev. 2011;5:CD005195. KQ3E9. [pmid: 21563143].
62 Dietrich M, Jacques PF, Pencina MJ, et al. Vitamin E supplement use and the incidence of cardiovascular disease and all-cause mortality in the Framingham Heart Study: Does the underlying health status play a role?. Atherosclerosis. Aug. 2009;205(2):549-53. KQ3E5, KQ4E5. [pmid: 19195657].
63 Dotan Y, Pinchuk I, Lichtenberg D, et al. Decision analysis supports the paradigm that indiscriminate supplementation of vitamin E does more harm than good. Arterioscler Thromb Vasc Biol. Sep. 2009;29(9):1304-9. KQ4E5. [pmid: 19286632].
64 Driscoll MS, Kwon EK, Skupsky H, et al. Nutrition and the deleterious side effects of nutritional supplements. Clin Dermatol. Jul. 2010;28(4):371-9. KQ4E5. [pmid: 20620752].
65 Druesne-Pecollo N, Latino-Martel P, Norat T, et al. Beta-carotene supplementation and cancer risk: a systematic review and metaanalysis of randomized controlled trials. Int J Cancer. Jul. 1. 2010;127(1):172-84. KQ3E9. [pmid: 19876916].
66 Duffield-Lillico AJ, Reid ME, Turnbull BW, et al. Baseline characteristics and the effect of selenium supplementation on cancer incidence in a randomized clinical trial: a summary report of the Nutritional Prevention of Cancer Trial. Cancer Epidemiol Biomarkers Prev. Jul. 2002;11(7):630-9. KQ4E6. [pmid: 12101110].
67 Duffield-Lillico AJ, Slate EH, Reid ME, et al. Selenium supplementation and secondary prevention of nonmelanoma skin cancer in a randomized trial. J Natl Cancer Inst. Oct. 1. 2003;95(19):1477-81. KQ3E3. [pmid: 14519754].
68 Duffield-Lillico AJ, Dalkin BL, Reid ME, et al. Selenium supplementation, baseline plasma selenium status and incidence of prostate cancer: an analysis of the complete treatment period of the Nutritional Prevention of Cancer Trial. BJU Int. May. 2003;91(7):608-12. KQ4E6. [pmid: 12699469].
69 Durga J, Bots ML, Schouten EG, et al. Effect of 3 y of folic acid supplementation on the progression of carotid intima-media thickness and carotid arterial stiffness in older adults. Am J Clin Nutr. May. 2011;93(5):941-9. KQ3E1, KQ4E1. [pmid: 21430116].
70 Earnest CP, Kupper JS, Thompson AM, et al. Complementary effects of multivitamin and omega-3 fatty acid supplementation on indices of cardiovascular health in individuals with elevated homocysteine. Int J Vitam Nutr Res. Feb. 2012;82(1):41-52. KQ1E6, KQ2E6. [pmid: 22811376].
71 Ebbing M, Bonaa KH, Nygard O, et al. Cancer incidence and mortality after treatment with folic acid and vitamin B12. JAMA. Nov. 18. 2009;302(19):2119-26. KQ3E3, KQ4E3. [pmid: 19920236].
72 Ebbing M, Bonaa KH, Arnesen E, et al. Combined analyses and extended follow-up of two randomized controlled homocysteine-lowering B-vitamin trials. J Intern Med. Oct. 2010;268(4):367-82. KQ3E3, KQ4E3. [pmid: 20698927].
73 Edvardsen K, Veierod MB, Brustad M, et al. Vitamin D-effective solar UV radiation, dietary vitamin D and breast cancer risk. Int J Cancer. Mar. 15. 2011;128(6):1425-33. KQ3E1, KQ4E1. [pmid: 20473950].
74 Ezzedine K, Latreille J, Kesse-Guyot E, et al. Incidence of skin cancers during 5-year follow-up after stopping antioxidant vitamins and mineral supplementation. Eur J Cancer. Dec. 2010;46(18):3316-22. KQ2E6. [pmid: 20605091].
75 Fenton A, Panay N. Calcium supplementation: is there a cardiovascular risk?. Climacteric. Feb. 2011;14(1):1-2. KQ4E5. [pmid: 21235419].
76 Fife J, Raniga S, Hider PN, et al. Folic acid supplementation and colorectal cancer risk: a meta-analysis. Colorectal Dis. Feb. 2011;13(2):132-7. KQ3E4. [pmid: 19863600].
77 Figueiredo JC, Mott LA, Giovannucci E, et al. Folic acid and prevention of colorectal adenomas: a combined analysis of randomized clinical trials. Int J Cancer. Jul. 1. 2011;129(1):192-203. KQ3E6. [pmid: 21170989].
78 Ford JA, MacLennan G, Bolland MJ, et al. Vitamin d supplementation prevents cardiac failure; MRC record trial analysis, systematic review and meta-analysis. Circulation. 2012;126:A18397. PMID: None. KQ4E6.
79 Forman MR, Levin B. Calcium plus vitamin D3 supplementation and colorectal cancer in women. New Engl J Med. 2006;354(7):752-4. KQ3E5, KQ4E5. [pmid: 16481644].
80 Frieling UM, Schaumberg DA, Kupper TS, et al. A randomized, 12-year primary-prevention trial of beta carotene supplementation for nonmelanoma skin cancer in the physician's health study. Arch Dermatol. Feb. 2000;136(2):179-84. KQ3E6, KQ4E6. [pmid: 10677093].
81 Fritz H, Kennedy D, Fernandes R, et al. Selenium and lung cancer: A systematic review. J Soc Integr Oncol. 2010;8(4):203-4. PMID: None. KQ3E4.
82 Fritz H, Kennedy D, Fernandes R, et al. Vitamin D and lung cancer: A systematic review. J Soc Integr Oncol. 2010;8(4):205. PMID: None. KQ3E4.
83 Fu T, Tang JY, Leblanc E, et al. Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer. J Invest Dermatol. 2011;131(Suppl 1):S35. PMID: None. KQ4E6.
84 Garland CF, French CB, Baggerly LL, et al. Vitamin D supplement doses and serum 25-hydroxyvitamin D in the range associated with cancer prevention. Anticancer Res. Feb. 2011;31(2):607-11. KQ3E1, KQ4E1. [pmid: 21378345].
85 Geleijnse JM. Vitamin D and the prevention of hypertension and cardiovascular diseases: a review of the current evidence. Am J Hypertens. Mar. 2011;24(3):253-62. KQ3E5, KQ4E5. [pmid: 20847727].
86 Gepner AD, Ramamurthy R, Krueger DC, et al. A prospective randomized controlled trial of the effects of vitamin D supplementation on cardiovascular disease risk. PLoS ONE. 2012;7(5):e36617. KQ3E6, KQ4E6. [pmid: 22586483].
87 Gerss J, Kopcke W. The questionable association of vitamin E supplementation and mortality--inconsistent results of different meta-analytic approaches. Cell Mol Biol. 2009;55:Suppl-20. KQ4E1. [pmid: 19267994].
88 Goodman GE, Thornquist MD, Balmes J, et al. The Beta-Carotene and Retinol Efficacy Trial: incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping beta-carotene and retinol supplements. J Natl Cancer Inst. Dec. 1. 2004;96(23):1743-50. KQ4E6. [pmid: 15572756].
89 Goodman PJ, Hartline JA, Tangen CM, et al. Moving a randomized clinical trial into an observational cohort. Clin Trials. 2013;10(1):131-42. KQ3E6, KQ4E6. [pmid: 23064404].
90 Greenberg ER, Baron JA, Tosteson TD, et al. A clinical trial of antioxidant vitamins to prevent colorectal adenoma. Polyp Prevention Study Group. N Engl J Med. Jul. 21. 1994;331(3):141-7. KQ1E6, KQ3E6. [pmid: 8008027].
91 Greenberg ER, Baron JA, Karagas MR, et al. Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. Mar. 6. 1996;275(9):699-703. KQ4E6. [pmid: 8594267].
92 Hankey GJ, Eikelboom J, Yi Q, et al. B vitamin supplementation and incidence of cancer in patients with previous stroke or transient ischemic attack (TIA): Results of a randomised trial. Int J Stroke. 2012;7(Suppl 1):43. PMID: None. KQ1E3, KQ2E3.
93 Hankey GJ, Eikelboom JW, Yi Q, et al. Treatment with B vitamins and incidence of cancer in patients with previous stroke or transient ischemic attack: results of a randomized placebo-controlled trial. Stroke. Jun. 2012;43(6):1572-7. KQ1E3, KQ2E6. [pmid: 22474057].
94 Hatfield DL, Gladyshev VN. The Outcome of Selenium and Vitamin E Cancer Prevention Trial (SELECT) reveals the need for better understanding of selenium biology. Mol Interv. Feb. 2009;9(1):18-21. KQ3E5. [pmid: 19299660].
95 Hatzitolios A, Iliadis F, Katsiki N, et al. Is the anti-hypertensive effect of dietary supplements via aldehydes reduction evidence based? A systematic review. Clin Exp Hypertens. Oct. 2008;30(7):628-39. KQ1E4. [pmid: 18855266].
96 Hayden KM, Welsh-Bohmer KA, Wengreen HJ, et al. Risk of mortality with vitamin E supplements: the Cache County study. Am J Med. Feb. 2007;120(2):180-4. KQ3E5, KQ4E5. [pmid: 17275460].
97 Hemila H, Kaprio J. Vitamin E supplementation may transiently increase tuberculosis risk in males who smoke heavily and have high dietary vitamin C intake. Br J Nutr. Oct. 2008;100(4):896-902. KQ3E6, KQ4E6. [pmid: 18279551].
98 Hemilä H, Kaprio J. Vitamin E supplementation may transiently increase tuberculosis risk in males who smoke heavily and have high dietary vitamin C intake. Br J Nutr. 2008;100(4):896-902. KQ3E6, KQ4E6. [pmid: 18279551].
99 Hercberg S, Czernichow S, Galan P. Antioxidant vitamins and minerals in prevention of cancers: lessons from the SU.VI.MAX study. Br J Nutr. Aug. 2006;96:Suppl-30. KQ2E6. [pmid: 16923246].
100 Hercberg S, Ezzedine K, Guinot C, et al. Antioxidant supplementation increases the risk of skin cancers in women but not in men. J Nutr. Sep. 2007;137(9):2098-105. KQ2E6. [pmid: 17709449].
101 Hercberg S, Kesse-Guyot E, Druesne-Pecollo N, et al. Incidence of cancers, ischemic cardiovascular diseases and mortality during 5-year follow-up after stopping antioxidant vitamins and minerals supplements: a postintervention follow-up in the SU.VI.MAX Study. Int J Cancer. Oct. 15. 2010;127(8):1875-81. KQ2E6. [pmid: 20104528].
102 Hernaandez J, Syed S, Weiss G, et al. The modulation of prostate cancer risk with alpha-tocopherol: a pilot randomized, controlled clinical trial. J Urol. Aug. 2005;174(2):519-22. KQ3E6. [pmid: 16006884].
103 Hernandez J, Syed S, Weiss G, et al. The modulation of prostate cancer risk with a-tocopherol: a pilot randomized, controlled clinical trial. J Urol. 2005;174(2):519-22. KQ3E6, KQ4E6. [pmid: 16006884].
104 Hsia J, Heiss G, Ren H, et al. Calcium/vitamin D supplementation and cardiovascular events. Circulation. Feb. 20. 2007;115(7):846-54. KQ4E6. [pmid: 17309935].
105 Ishitani K, Lin J, Manson JE, et al. A prospective study of multivitamin supplement use and risk of breast cancer. Am J Epidemiol. 2008;167(10):1197-206. KQ1E5, KQ2E6. [pmid: 18344515].
106 Jackson RD, LaCroix AZ, Cauley JA, et al. The Women's Health Initiative calcium-vitamin D trial: overview and baseline characteristics of participants. Ann Epidemiol. Oct. 2003;13(9 Suppl):S98-106. KQ3E6. [pmid: 14575942].
107 Jiang L, Yang KH, Tian JH, et al. Efficacy of antioxidant vitamins and selenium supplement in prostate cancer prevention: a meta-analysis of randomized controlled trials. Nutr Cancer. Aug. 2010;62(6):719-27. KQ3E9. [pmid: 20661819].
108 Johnson AR, Munoz A, Gottlieb JL, et al. High dose zinc increases hospital admissions due to genitourinary complications. J Urol. Feb. 2007;177(2):639-43. KQ4E11. [pmid: 17222649].
109 Kataja-Tuomola MK, Kontto JP, Mannisto S, et al. Intake of antioxidants and risk of type 2 diabetes in a cohort of male smokers. Eur J Clin Nutr. 2011;65(5):590-7. KQ3E5. [pmid: 21245884].
110 Kennedy DA, Stern SJ, Moretti M, et al. Folate intake and the risk of colorectal cancer: a systematic review and meta-analysis. Cancer Epidemiol. Feb. 2011;35(1):2-10. KQ3E4. [pmid: 21177150].
111 Kesse-Guyot E, Touvier M, Henegar A, et al. Higher adherence to French dietary guidelines and chronic diseases in the prospective SU.VI.MAX cohort. Eur J Clin Nutr. Aug. 2011;65(8):887-94. KQ3E1, KQ4E1. [pmid: 21559045].
112 Kirsh VA, Hayes RB, Mayne ST, et al. Supplemental and dietary vitamin E, beta-carotene, and vitamin C intakes and prostate cancer risk. J Natl Cancer Inst. Feb. 15. 2006;98(4):245-54. KQ3E5, KQ4E5. [pmid: 16478743].
113 Kristal AR, Arnold KB, Neuhouser ML, et al. Diet, supplement use, and prostate cancer risk: results from the prostate cancer prevention trial. Am J Epidemiol. Sep. 1. 2010;172(5):566-77. KQ3E5. [pmid: 20693267].
114 Larsson SC, Wolk A. Magnesium intake and risk of type 2 diabetes: a meta-analysis. J Intern Med. Aug. 2007;262(2):208-14. KQ3E1, KQ4E1. [pmid: 17645588].
115 Larsson SC, Akesson A, Bergkvist L, et al. Multivitamin use and breast cancer incidence in a prospective cohort of Swedish women. Am J Clin Nutr. May. 2010;91(5):1268-72. KQ2E10. [pmid: 20335555].
116 Larsson SC, Orsini N, Wolk A. Vitamin B6 and risk of colorectal cancer: a meta-analysis of prospective studies. JAMA. Mar. 17. 2010;303(11):1077-83. KQ3E1. [pmid: 20233826].
117 Lawson KA, Wright ME, Subar A, et al. Multivitamin use and risk of prostate cancer in the National Institutes of Health-AARP Diet and Health Study. J Natl Cancer Inst. May. 16. 2007;99(10):754-64. KQ2E5, KQ3E5, KQ4E5. [pmid: 17505071].
118 Ledesma MC, Jung-Hynes B, Schmit TL, et al. Selenium and vitamin E for prostate cancer: Post SELECT (selenium and vitamin E cancer prevention trial) status. Mol Med. 2011;17(1-2):134-43. KQ3E5. [pmid: 20882260].
119 Lee JE, Li H, Chan AT, et al. Circulating levels of vitamin D and colon and rectal cancer: the Physicians' Health Study and a meta-analysis of prospective studies. Cancer Prev Res. May. 2011;4(5):735-43. KQ3E1. [pmid: 21430073].
120 Lee JE, Willett WC, Fuchs CS, et al. Folate intake and risk of colorectal cancer and adenoma: modification by time. Am J Clin Nutr. Apr. 2011;93(4):817-25. KQ3E5, KQ4E6. [pmid: 21270374].
121 Lee M, Hong KS, Chang SC, et al. Efficacy of homocysteine-lowering therapy with folic Acid in stroke prevention: a meta-analysis. Stroke. Jun. 2010;41(6):1205-12. KQ3E3. [pmid: 20413740].
122 Leppala JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arterioscler Thromb Vasc Biol. Jan. 2000;20(1):230-5. KQ3E6. [pmid: 10634823].
123 Lewis JR, Calver J, Zhu K, et al. Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res. Jan. 2011;26(1):35-41. KQ3E3, KQ4E3. [pmid: 20614474].
124 Li J, Hou Z. Whether vitamin E supplements can decrease the risk of prostate cancer: Meta analysis. J Clin Rehab Tissue Eng Res. 2010;14(28):5177-80. PMID: None. KQ3E8.
125 Li K, Kaaks R, Linseisen J, et al. Associations of dietary calcium intake and calcium supplementation with myocardial infarction and stroke risk and overall cardiovascular mortality in the Heidelberg cohort of the European Prospective Investigation into Cancer and Nutrition study (EPIC-Heidelberg). Heart. Jun. 2012;98(12):920-5. KQ3E5, KQ4E5. [pmid: 22626900].
126 Li K, Kaaks R, Linseisen J, et al. Vitamin/mineral supplementation and cancer, cardiovascular, and all-cause mortality in a German prospective cohort (EPIC-Heidelberg). Eur J Nutr. Jun. 2012;51(4):407-13. KQ1E5, KQ2E6. [pmid: 21779961].
127 Lin J, Cook NR, Albert C, et al. Vitamins C and E and beta carotene supplementation and cancer risk: a randomized controlled trial. J Natl Cancer Inst. Jan. 7. 2009;101(1):14-23. KQ3E3. [pmid: 19116389].
128 Loke YK, Price D, Derry S, et al. Case reports of suspected adverse drug reactions--systematic literature survey of follow-up. BMJ. Feb. 11. 2006;332(7537):335-9. KQ2E1, KQ4E1. [pmid: 16421149].
129 Lonn E, Bosch J, Yusuf S, et al. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. Mar. 16. 2005;293(11):1338-47. KQ3E3. [pmid: 15769967].
130 Lopez-Torres HJ, ANVITAD Group. Prevention of falls and fractures in old people by administration of calcium and vitamin D. randomized clinical trial. BMC Public Health. 2011;11:910. KQ4E9. [pmid: 22151975].
131 Lotan Y, Goodman P, Youssef R, et al. Evaluation of vitamin E and selenium supplementation on the prevention of bladder cancer in swog-coordinated select. J Urol. 2012;187(6):2005-10. KQ4E6. [pmid: 22498220].
132 Magliano D, McNeil J, Branley P, et al. The Melbourne Atherosclerosis Vitamin E Trial (MAVET): a study of high dose vitamin E in smokers. Eur J Cardiovasc Prev Rehabil. Jun. 2006;13(3):341-7. KQ3E6. [pmid: 16926662].
133 Malila N, Virtamo J, Virtanen M, et al. The effect of alpha-tocopherol and beta-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol Biomarkers Prev. Jun. 1999;8(6):489-93. KQ3E6, KQ4E6. [pmid: 10385137].
134 Manson JE, Bassuk SS, Lee IM, et al. The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. Jan. 2012;33(1):159-71. KQ3E9, KQ4E9. [pmid: 21986389].
135 Margolis KL, Ray RM, Van HL, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension. Nov. 2008;52(5):847-55. KQ3E6. [pmid: 18824662].
136 Margolis KL, Ray RM, Kerby TJ. The womens health initiative calcium/vitamin D trial. Hypertension. 2011;57(4):e14. KQ3E5. [pmid: 21357276].
137 Mark SD, Wang W, Fraumeni JF Jr, et al. Do nutritional supplements lower the risk of stroke or hypertension?. Epidemiology. Jan. 1998;9(1):9-15. KQ1E2, KQ3E2. [pmid: 9430262].
138 Martini LA, Catania AS, Ferreira SRG. Role of vitamins and minerals in prevention and management of type 2 diabetes mellitus. Nutr Rev. 2010;68(6):341-54. KQ3E5. [pmid: 20536779].
139 Mazdak H, Zia H. Vitamin E reduces superficial bladder cancer recurrence: A randomized controlled trial. Int J Prev Med. 2012;3(2):110-5. KQ3E6, KQ4E6. [pmid: 22347607].
140 McCullough ML, Bandera EV, Moore DF, et al. Vitamin D and calcium intake in relation to risk of endometrial cancer: a systematic review of the literature. Prev Med. Apr. 2008;46(4):298-302. KQ3E9. [pmid: 18155758].
141 McNeil JJ, Robman L, Tikellis G, et al. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. Jan. 2004;111(1):75-84. KQ3E6, KQ4E6. [pmid: 14711717].
142 Meydani SN, Meydani M, Blumberg JB, et al. Assessment of the safety of supplementation with different amounts of vitamin E in healthy older adults. Am J Clin Nutr. Aug. 1998;68(2):311-8. KQ3E6, KQ4E6. [pmid: 9701188].
143 Michaud DS. Vitamin D and pancreatic cancer risk in the alpha-tocopherol, beta-carotene cancer prevention cohort. Cancer Res. Oct. 15. 2006;66(20):9802-3. KQ3E5, KQ4E5. [pmid: 17047039].
144 Miller ER III, Pastor-Barriuso R, Dalal D, et al. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Ann Intern Med. Jan. 4. 2005;142(1):37-46. KQ4E9. [pmid: 15537682].
145 Miller ER III, Juraschek S, Pastor-Barriuso R, et al. Meta-analysis of folic acid supplementation trials on risk of cardiovascular disease and risk interaction with baseline homocysteine levels. Am J Cardiol. Aug. 15. 2010;106(4):517-27. KQ3E9. [pmid: 20691310].
146 Moon TE, Levine N, Cartmel B, et al. Effect of retinol in preventing squamous cell skin cancer in moderate-risk subjects: a randomized, double-blind, controlled trial. Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. Nov. 1997;6(11):949-56. KQ3E6. [pmid: 9367069].
147 Mursu J, Robien K, Harnack LJ, et al. Dietary supplements and mortality rate in older women: The Iowa Women's Health Study. Arch Intern Med. 2011;171(18):1625-33. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 21987192].
148 Myung SK, Kim Y, Ju W, et al. Effects of antioxidant supplements on cancer prevention: Meta-analysis of randomized controlled trials. Ann Oncol. 2010;21(1):166-79. KQ3E9. [pmid: 19622597].
149 Ntaios G, Savopoulos C, Grekas D, et al. The controversial role of B-vitamins in cardiovascular risk: An update. Arch Cardiovasc Dis. 2009;102(12):847-54. KQ3E5, KQ4E5. [pmid: 19963194].
150 Omenn GS, Goodman GE, Thornquist M, et al. Long-term vitamin A does not produce clinically significant hypertriglyceridemia: results from CARET, the beta-carotene and retinol efficacy trial. Cancer Epidemiol Biomarkers Prev. Dec. 1994;3(8):711-3. KQ3E6, KQ4E6. [pmid: 7881345].
151 Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the Beta-Carotene and Retinol Efficacy Trial. J Natl Cancer Inst. Nov. 6. 1996;88(21):1550-9. KQ4E6. [pmid: 8901853].
152 Peters U, Littman AJ, Kristal AR, et al. Vitamin E and selenium supplementation and risk of prostate cancer in the Vitamins and lifestyle (VITAL) study cohort. Cancer Causes Control. Feb. 2008;19(1):75-87. KQ3E5. [pmid: 17943452].
153 Pilz S, Tomaschitz A, Drechsler C, et al. Vitamin D supplementation: a promising approach for the prevention and treatment of strokes. Curr Drug Targets. Jan. 2011;12(1):88-96. KQ3E5. [pmid: 20795935].
154 Pittas AG, Lau J, Hu FB, et al. The role of vitamin D and calcium in type 2 diabetes. A systematic review and meta-analysis. J Clin Endocrinol Metab. Jun. 2007;92(6):2017-29. KQ3E9. [pmid: 17389701].
155 Pittas AG, Chung M, Trikalinos T, et al. Systematic review: Vitamin D and cardiometabolic outcomes. Ann Intern Med. Mar. 2. 2010;152(5):307-14. KQ3E9. [pmid: 20194237].
156 Prince RL, Devine A, Dhaliwal SS, et al. Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med. Apr. 24. 2006;166(8):869-75. KQ4E6. [pmid: 16636212].
157 Rapola JM, Virtamo J, Haukka JK, et al. Effect of vitamin E and beta carotene on the incidence of angina pectoris. A randomized, double-blind, controlled trial. JAMA. Mar. 6. 1996;275(9):693-8. KQ3E6. [pmid: 8594266].
158 Rapola JM, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. Jun. 14. 1997;349(9067):1715-20. KQ3E3, KQ4E3. [pmid: 9193380].
159 Rayman MP, Blundell-Pound G, Pastor-Barriuso R, et al. A randomized trial of selenium supplementation and risk of type-2 diabetes, as assessed by plasma adiponectin. PLoS ONE. 2012;7(9):e45269. KQ3E6. [pmid: 23028897].
160 Reid IR, Mason B, Horne A, et al. Effects of calcium supplementation on serum lipid concentrations in normal older women: a randomized controlled trial. Am J Med. Apr. 1. 2002;112(5):343-7. KQ3E6. [pmid: 11904107].
161 Reid IR, Bolland MJ. Calcium supplementation and vascular disease. Climacteric. Aug. 2008;11(4):280-6. KQ4E5. [pmid: 18645693].
162 Reid IR, Ames R, Mason B, et al. Randomized controlled trial of calcium supplementation in healthy, nonosteoporotic, older men. Arch Intern Med. Nov. 10. 2008;168(20):2276-82. KQ4E6. [pmid: 19001206].
163 Reid IR, Bolland MJ, Avenell A, et al. Cardiovascular effects of calcium supplementation. Osteoporos Int. Jun. 2011;22(6):1649-58. KQ3E5, KQ4E5. [pmid: 21409434].
164 Reid ME, Duffield-Lillico AJ, Sunga A, et al. Selenium supplementation and colorectal adenomas: an analysis of the nutritional prevention of cancer trial. Int J Cancer. Apr. 1. 2006;118(7):1777-81. KQ3E6. [pmid: 16217756].
165 Reid ME, Duffield-Lillico AJ, Slate E, et al. The nutritional prevention of cancer: 400 mcg per day selenium treatment. Nutr Cancer. 2008;60(2):155-63. KQ4E6. [pmid: 18444146].
166 Rexrode KM, Lee IM, Cook NR, et al. Baseline characteristics of participants in the Women's Health Study. J Womens Health Gend Based Med. Jan. 2000;9(1):19-27. KQ3E6, KQ4E6. [pmid: 10718501].
167 Rogovik AL, Vohra S, Goldman RD. Safety considerations and potential interactions of vitamins: should vitamins be considered drugs?. Ann Pharmacother. Feb. 2010;44(2):311-24. KQ4E11. [pmid: 20040703].
168 Rohan TE, Negassa A, Chlebowski RT, et al. A randomized controlled trial of calcium plus vitamin D supplementation and risk of benign proliferative breast disease. Breast Cancer Res Treat. Jul. 2009;116(2):339-50. KQ3E6. [pmid: 18853250].
169 Sacco M, Pellegrini F, Roncaglioni MC, et al. Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. Dec. 2003;26(12):3264-72. KQ3E3. [pmid: 14633812].
170 Salehpour A, Shidfar F, Hosseinpanah F, et al. Vitamin D3 and the risk of CVD in overweight and obese women: A randomised controlled trial. Br J Nutr. 2012;108(10):1866-73. KQ3E6, KQ4E6. [pmid: 22317756].
171 Satia JA, Littman A, Slatore CG, et al. Long-term use of beta-carotene, retinol, lycopene, and lutein supplements and lung cancer risk: results from the VITamins And Lifestyle (VITAL) study. Am J Epidemiol. Apr. 1. 2009;169(7):815-28. KQ4E10. [pmid: 19208726].
172 Sauer J, Mason JB, Choi SW. Too much folate: A risk factor for cancer and cardiovascular disease?. Curr Opin Clin Nutr Metab Care. 2009;12(1):30-6. KQ4E5. [pmid: 19057184].
173 Schulze MB, Schulz M, Heidemann C, et al. Fiber and magnesium intake and incidence of type 2 diabetes: a prospective study and meta-analysis. Arch Intern Med. May. 14. 2007;167(9):956-65. KQ3E1, KQ4E1. [pmid: 17502538].
174 Shah SM, Carey IM, Harris T, et al. Calcium supplementation, cardiovascular disease and mortality in older women. Pharmacoepidemiol Drug Saf. Jan. 2010;19(1):59-64. KQ3E5, KQ4E5. [pmid: 19757413].
175 Slatore CG, Littman AJ, Au DH, et al. Long-term use of supplemental multivitamins, vitamin C, vitamin E, and folate does not reduce the risk of lung cancer. Am J Respir Crit Care Med. Mar. 1. 2008;177(5):524-30. KQ1E5, KQ3E5. [pmid: 17989343].
176 Song Y, Cook NR, Christine MA, et al. Effects of vitamins C and E and beta-carotene on the incidence of type 2 diabetes mellitus in the Women's Antioxidant Cardiovascular Study randomized controlled trial. Am J Epidemiol. 2008;167(Suppl 11):S146. PMID: None. KQ3E3.
177 Sood A, Arora R. Mechanisms of flushing due to niacin and abolition of these effects. J Clin Hypertens. Nov. 2009;11(11):685-9. KQ4E5. [pmid: 19878384].
178 Stampfer M, Rimm E, Willett W. Folate supplementation and cardiovascular disease. Lancet. 2006;367(9518):1237-8. KQ3E5, KQ4E5. [pmid: 16631874].
179 Stranges S, Marshall JR, Trevisan M, et al. Effects of selenium supplementation on cardiovascular disease incidence and mortality: secondary analyses in a randomized clinical trial. Am J Epidemiol. Apr. 15. 2006;163(8):694-9. KQ4E6. [pmid: 16495471].
180 Stratton J, Godwin M. The effect of supplemental vitamins and minerals on the development of prostate cancer: a systematic review and meta-analysis. Fam Pract. Jun. 2011;28(3):243-52. KQ1E9. [pmid: 21273283].
181 Stratton MS, Reid ME, Schwartzberg G, et al. Selenium and prevention of prostate cancer in high-risk men: the Negative Biopsy Study. Anticancer Drugs. Sep. 2003;14(8):589-94. KQ3E4, KQ4E4. [pmid: 14501380].
182 Tanvetyanon T, Bepler G. Beta-carotene in multivitamins and the possible risk of lung cancer among smokers versus former smokers: a meta-analysis and evaluation of national brands. Cancer. Jul. 1. 2008;113(1):150-7. KQ3E9, KQ4E9. [pmid: 18429004].
183 Taylor PR, Li B, Dawsey SM, et al. Prevention of esophageal cancer: the nutrition intervention trials in Linxian, China. Linxian Nutrition Intervention Trials Study Group. Cancer Res. Apr. 1. 1994;54(7 Suppl):2029s-31s. KQ1E2, KQ3E2. [pmid: 8137333].
184 Thomas J. Multivitamins associated with increased cancer outcomes and all-cause mortality. Aust J Pharm. 2010;91(1081):74. PMID: None. KQ2E5, KQ3E5, KQ4E5.
185 Tornwall ME, Virtamo J, Korhonen PA, et al. Postintervention effect of alpha tocopherol and beta carotene on different strokes: a 6-year follow-up of the Alpha Tocopherol, Beta Carotene Cancer Prevention Study. Stroke. Aug. 2004;35(8):1908-13. KQ3E6. [pmid: 15205487].
186 Touvier M, Kesse E, Clavel-Chapelon F, et al. Dual Association of beta-carotene with risk of tobacco-related cancers in a cohort of French women. J Natl Cancer Inst. Sep. 21. 2005;97(18):1338-44. KQ3E5, KQ4E5. [pmid: 16174855].
187 Varis K, Taylor PR, Sipponen P, et al. Gastric cancer and premalignant lesions in atrophic gastritis: a controlled trial on the effect of supplementation with alpha-tocopherol and beta-carotene. The Helsinki Gastritis Study Group. Scand J Gastroenterol. Mar. 1998;33(3):294-300. KQ3E6. [pmid: 9548624].
188 Vassilev ZP, Chu AF, Ruck B, et al. Evaluation of adverse drug reactions reported to a poison control center between 2000 and 2007. Am J Health Syst Pharm. 2009;66(5 SUPPL. 3):X481-X487. KQ2E5, KQ4E5. [pmid: 19233996].
189 Virtamo J, Edwards BK, Virtanen M, et al. Effects of supplemental alpha-tocopherol and beta-carotene on urinary tract cancer: incidence and mortality in a controlled trial (Finland). Cancer Causes Control. Dec. 2000;11(10):933-9. KQ4E6. [pmid: 11142528].
190 VITATOPS Trial Study Group, Hankey GJ, Algra A, et al. VITATOPS, the VITAmins TO prevent stroke trial: rationale and design of a randomised trial of B-vitamin therapy in patients with recent transient ischaemic attack or stroke (NCT00097669) (ISRCTN74743444). Int J Stroke. May. 2007;2(2):144-50. KQ1E3. [pmid: 18705976].
191 VITATOPS Trial Study Group. B vitamins in patients with recent transient ischaemic attack or stroke in the VITAmins TO Prevent Stroke (VITATOPS) trial: a randomised, double-blind, parallel, placebo-controlled trial. Lancet Neurology. Sep. 2010;9(9):855-65. KQ1E3, KQ2E3. [pmid: 20688574].
192 Walsh PC. Re: Vitamin e and the risk of prostate cancer: The Selenium and Vitamin e Cancer Prevention Trial (SELECT). J Urol. 2012;187(5):1640-1. KQ4E6. [pmid: 22494720].
193 Wang GQ, Dawsey SM, Li JY, et al. Effects of vitamin/mineral supplementation on the prevalence of histological dysplasia and early cancer of the esophagus and stomach: results from the General Population Trial in Linxian, China. Cancer Epidemiol Biomarkers Prev. Mar. 1994;3(2):161-6. KQ1E2, KQ3E2. [pmid: 8049638].
194 Wang L, Manson JE, Song Y, et al. Systematic review: Vitamin D and calcium supplementation in prevention of cardiovascular events. Ann Intern Med. Mar. 2. 2010;152(5):315-23. KQ3E9, KQ4E9. [pmid: 20194238].
195 Wang X, Qin X, Demirtas H, et al. Efficacy of folic acid supplementation in stroke prevention: a meta-analysis. Lancet. Jun. 2. 2007;369(9576):1876-82. KQ3E3. [pmid: 17544768].
196 Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. Cochrane Database Syst Rev. 2008;(1):CD003548. KQ3E9. [pmid: 18254022].
197 Wolf RL, Cauley JA, Pettinger M, et al. Lack of a relation between vitamin and mineral antioxidants and bone mineral density: results from the Women's Health Initiative. Am J Clin Nutr. Sep. 2005;82(3):581-8. KQ3E6, KQ4E6. [pmid: 16155271].
198 Wyatt G. Vitamin E increases prostate cancer risk in middle-aged men relative to placebo: no significant association observed with selenium, either alone or in combination with vitamin E. Evid Based Nurs. Jul. 2012;15(3):90-1. KQ4E6. [pmid: 22411161].
199 Xuan XZ, Schatzkin A, Mao BL, et al. Feasibility of conducting a lung-cancer chemoprevention trial among tin miners in Yunnan, P. R. China. Cancer Causes Control. May. 1991;2(3):175-82. KQ2E3, KQ4E3. [pmid: 1873448].
200 Zhang SM, Moore SC, Lin J, et al. Folate, vitamin B6, multivitamin supplements, and colorectal cancer risk in women. Am J Epidemiol. Jan. 15. 2006;163(2):108-15. KQ3E5, KQ4E5. [pmid: 16339055].
201 Zhang SM, Cook NR, Albert CM, et al. Effect of combined folic acid, vitamin B6, and vitamin B12 on cancer risk in women: a randomized trial. JAMA. Nov. 5. 2008;300(17):2012-21. KQ1E3, KQ3E3, KQ4E3. [pmid: 18984888].