# Ongoing or Recently Completed Studies

Study | Design | Aim | Location | Number of participants | Intervention description | Relevant outcomes | 2013 status
Adjei 2012^188^ | Open-label | Determine side effects and best dose of calcitriol in preventing lung cancer in current and former smokers at high risk for lung cancer | United States | NR | Oral vitamin D every 2 weeks | Adverse effects, toxicities | Estimated completion, December 2015
Camargo, 2011^189^ | RCT | Determine the effect of vitamin D supplementation on cardiovascular disease event rates | New Zealand | 5,100 | Vitamin D_3_ 200,000 IU at baseline; 100,000 IU monthly | Cardiovascular disease | Estimated completion, 2017
Goossens 2012 (Selenium and Bladder Cancer Trial)190 | RCT | Determine the effect of selenium supplementation on bladder cancer recurrence | Belgium | 900 | Selenium 200 mcg qd | Serious adverse events | Estimated completion, October 2014
Lance 2011 (Selenium and Vitamin E Cancer Prevention Trial)191 | RCT | Determine the effect of vitamin E and/or selenium on colorectal polyps in men enrolled in the SELECT trial | United States | NR | Selenium ± vitamin E | Colorectal cancer | Estimated completion, June 2013
Lappe 2012 (CAPS)192 | RCT | Determine the effect of vitamin D_3_ supplementation on all types of cancer incidence | United States | 2,300 | Vitamin D_3_ 2,000 IU qd + calcium 1,500 mg qd | Cancer | Estimated completion, June 2014
Lopez-Torres 2011^193^ | RCT | Determine effectiveness of calcium and vitamin D supplementation in improving musculoskeletal function and decreasing the number of falls in older adults | Spain | 704 | Vitamin D 800 IU qd + calcium 1,200 mg qd | Falls, fractures, and adverse effects | Published study protocol
Manson 2012 (Vitamin D and Omega-3 Trial)194 | RCT, 2×2 factorial design | Determine if vitamin D_3_ supplementation (with or without marine omega-3 fatty acid) reduces risk for total cancer and major cardiovascular disease events | United States | 20,000 | Vitamin D_3_ 2,000 IU qd | Cancer, MI, and stroke | Published methods; estimated completion, 2017
Peto 2012 (Vitamin D and Longevity Trial [VIDAL])195 | RCT | Determine the feasibility of a large RCT measuring the effect of oral vitamin D on morbidity and mortality in older adults | United Kingdom | 20,000 | Vitamin D 60,000 IU monthly | Mortality | Estimated completion, 2020
Rhodes 2009^196^ | RCT | Examine effect of green tea and vitamin C on the health of human skin | United States | 50 | Vitamin C 100 mg with green tea qd | Skin cancer | Estimated completion, August 2012
Tran 2012^197^ | RCT | Examine the effect of vitamin D supplementation on cancer incidence and overall mortality | Australia | 644 | Vitamin D 30,000 to 60,000 IU monthly | Cancer, mortality | Published recruitment results, 2012
Tuomainen 2011 (Finnish Vitamin D Trial)198 | RCT | Determine benefits and risks of vitamin D supplementation in the primary prevention of cardiovascular disease and cancer | Finland | 18,000 | Vitamin D_3_ 1,600 to 3,200 IU qd | Cardiovascular disease, MI, stroke, TIA, angina, cancer, adverse effects | Estimated completion, December 2019

Abbreviations: MI = myocardial infarction; NR = not reported; qd = once a day; RCT = randomized, controlled trial; SELECT = Selenium and Vitamin E Cancer Prevention Trial; TIA = transient ischemic attack.