# Detailed Methods

Literature Search Strategies
- Database: Ovid MEDLINE(R) without Revisions <1996 to April Week 4 2012>, Ovid MEDLINE(R) Daily Update <January 29, 2013>
  1. Calcium, dietary/
  2. dietary calcium.ti,ab.
  3. calcium supplement*.ti,ab.
  4. folic acid/
  5. folic acid.ti,ab.
  6. folate.ti,ab.
  7. Thiamine/
  8. Thiamine.ti,ab.
  9. Thiamin.ti,ab.
  10. Thiamine Monophosphate/
  11. Thiamine Pyrophosphate/
  12. Thiamine Triphosphate/
  13. Vitamin B 1.ti,ab.
  14. Vitamin B1.ti,ab.
  15. Aneurin.ti,ab.
  16. Riboflavin/
  17. Riboflavin.ti,ab.
  18. Vitamin B 2.ti,ab.
  19. Vitamin B2.ti,ab.
  20. Vitamin B 6/
  21. Vitamin B 6.ti,ab.
  22. Vitamin B6.ti,ab.
  23. Pyridoxine/
  24. Pyridoxine.ti,ab.
  25. Vitamin B 12/
  26. Vitamin B 12.ti,ab.
  27. Vitamin B12.ti,ab.
  28. Cobamides/
  29. Hydroxocobalamin/
  30. Cobalamin.ti,ab.
  31. Cyanocobalamin.ti,ab.
  32. Cobamides.ti,ab.
  33. Hydroxocobalamin.ti,ab.
  34. Vitamin D/
  35. Vitamin D.ti,ab.
  36. Cholecalciferol/
  37. Cholecalciferol.ti,ab.
  38. Dihydroxycholecalciferols/
  39. Dihydroxycholecalciferol*.ti,ab.
  40. Calcitriol/
  41. Calcitriol.ti,ab.
  42. Ergocalciferols/
  43. Ergocalciferol*.ti,ab.
  44. Vitamin E/
  45. Vitamin E.ti,ab.
  46. Tocopherols/
  47. Tocopherol*.ti,ab.
  48. Tocotrienols/
  49. Tocotrienol*.ti,ab.
  50. Ascorbic acid/
  51. Ascorbic acid.ti,ab.
  52. Vitamin C.ti,ab.
  53. ascorbate.ti,ab.
  54. Vitamin A/
  55. Vitamin A.ti,ab.
  56. beta carotene/
  57. beta carotene.ti,ab.
  58. Retinol.ti,ab.
  59. iron, dietary/
  60. (iron adj5 dietary).ti,ab.
  61. (iron adj5 supplement*).ti,ab.
  62. zinc/
  63. (zinc adj5 dietary).ti,ab.
  64. (zinc adj5 supplement*).ti,ab.
  65. Magnesium/
  66. Magnesium Compounds/
  67. (magnesium adj5 dietary).ti,ab.
  68. (magnesium adj5 supplement*).ti,ab.
  69. Niacin/
  70. Niacin.ti,ab.
  71. Nicotinic acids/
  72. Nicotinic acid*.ti,ab.
  73. Selenium/
  74. Selenium compounds/
  75. Selenium.ti,ab.
  76. Vitamins/
  77. Minerals/
  78. (Vitamin* adj5 dietary).ti,ab.
  79. (Vitamin* adj5 supplement*).ti,ab.
  80. (mineral* adj5 dietary).ti,ab.
  81. (mineral* adj5 supplement*).ti,ab.
  82. Multivitamin*.ti,ab.
  83. multimineral*.ti,ab.
  84. or/1-83
  85. Cardiovascular Diseases/
  86. Heart Diseases/
  87. cardiovascular disease*.ti,ab.
  88. heart disease*.ti,ab.
  89. exp Arrhythmias, Cardiac/
  90. exp Cardiomyopathies/
  91. exp Heart Arrest/
  92. exp Heart Failure/
  93. exp Myocardial Ischemia/
  94. exp Ventricular Dysfunction/
  95. myocardial infarction.ti,ab.
  96. Heart arrest.ti,ab.
  97. myocardial isch?emia.ti,ab.
  98. Coronary artery disease.ti,ab.
  99. heart attack*.ti,ab.
  100. Isch?emic heart disease.ti,ab.
  101. Vascular Diseases/
  102. exp Aneurysm/
  103. exp Arterial Occlusive Diseases/
  104. Cerebrovascular Disorders/
  105. exp Carotid Artery Diseases/
  106. exp Stroke/
  107. exp Diabetic Angiopathies/
  108. exp Hypertension/
  109. Peripheral Vascular Diseases/
  110. Peripheral Arterial Disease/
  111. Prehypertension/
  112. Stroke.ti,ab.
  113. Hypertension.ti,ab.
  114. Cerebrovascular disease*.ti,ab.
  115. Cerebrovascular disorder*.ti,ab.
  116. Carotid artery disease*.ti,ab.
  117. exp Hyperlipidemias/
  118. Hyperlipid?emia*.ti,ab.
  119. Hypercholesterol?emia*.ti,ab.
  120. High cholesterol.ti,ab.
  121. Elevated cholesterol.ti,ab.
  122. Neoplasms/
  123. exp Abdominal Neoplasms/
  124. exp Bone Neoplasms/
  125. exp Breast Neoplasms/
  126. exp Digestive System Neoplasms/
  127. exp Endocrine Gland Neoplasms/
  128. exp Eye Neoplasms/
  129. exp “Head and Neck Neoplasms”/
  130. exp Hematologic Neoplasms/
  131. exp Nervous System Neoplasms/
  132. exp Pelvic Neoplasms/
  133. exp Skin Neoplasms/
  134. exp Soft Tissue Neoplasms/
  135. Splenic Neoplasms/
  136. exp Thoracic Neoplasms/
  137. exp Urogenital Neoplasms/
  138. exp Intestinal Polyps/
  139. lung cancer.ti,ab.
  140. lung neoplas*.ti,ab.
  141. breast cancer.ti,ab.
  142. Breast neoplas*.ti,ab.
  143. colorectal cancer.ti,ab.
  144. Colorectal neoplas*.ti,ab.
  145. prostate cancer.ti,ab.
  146. Prostatic neoplas*.ti,ab.
  147. gastric cancer.ti,ab.
  148. stomach cancer.ti,ab.
  149. Stomach neoplas*.ti,ab.
  150. Abdominal neoplas*.ti,ab.
  151. colorectal polyps.ti,ab.
  152. Colon* polyps.ti,ab.
  153. adenomas.ti,ab.
  154. or/85-153
  155. 84 and 154
  156. Randomized controlled trial.pt.
  157. controlled clinical trial.pt.
  158. Meta analysis.pt.
  159. Random allocation/
  160. double-blind method/
  161. single-blind method/
  162. Random*.ti,ab.
  163. (control* adj3 trial*).ti,ab.
  164. placebo*.ti,ab.
  165. controlled clinical trials as topic/
  166. randomized controlled trials as topic/
  167. meta analysis as topic/
  168. systematic review*.ti,ab.
  169. systematic evidence review*.ti,ab.
  170. meta analy*.ti,ab.
  171. metaanaly*.ti,ab.
  172. or/156-171
  173. 155 and 172
  174. limit 173 to animals
  175. limit 173 to humans
  176. 174 not 175
  177. 173 not 176
  178. limit 177 to english language
  179. limit 178 to yr=”2005 -Current”
  180. Calcium, dietary/
  181. dietary calcium.ti,ab.
  182. calcium supplement*.ti,ab.
  183. folic acid/
  184. folic acid.ti,ab.
  185. folate.ti,ab.
  186. Vitamin D/
  187. Vitamin D.ti,ab.
  188. Cholecalciferol/
  189. Cholecalciferol.ti,ab.
  190. Dihydroxycholecalciferols/
  191. Dihydroxycholecalciferol*.ti,ab.
  192. Calcitriol/
  193. Calcitriol.ti,ab.
  194. Ergocalciferols/
  195. Ergocalciferol*.ti,ab.
  196. Vitamin E/
  197. Vitamin E.ti,ab.
  198. Tocopherols/
  199. Tocopherol*.ti,ab.
  200. Tocotrienols/
  201. Tocotrienol*.ti,ab.
  202. Vitamin A/
  203. Vitamin A.ti,ab.
  204. beta carotene/
  205. beta carotene.ti,ab.
  206. Retinol.ti,ab.
  207. iron, dietary/
  208. (iron adj5 dietary).ti,ab.
  209. (iron adj5 supplement*).ti,ab.
  210. Selenium/
  211. Selenium compounds/
  212. Selenium.ti,ab.
  213. Vitamins/
  214. Minerals/
  215. (Vitamin* adj5 dietary).ti,ab.
  216. (Vitamin* adj5 supplement*).ti,ab.
  217. (mineral* adj5 dietary).ti,ab.
  218. (mineral* adj5 supplement*).ti,ab.
  219. Multivitamin*.ti,ab.
  220. multimineral*.ti,ab.
  221. or/180-220
  222. safety/
  223. safety.ti,ab.
  224. adverse event*.ti,ab.
  225. adverse effects.fs.
  226. adverse effect*.ti,ab.
  227. side effect*.ti,ab.
  228. product surveillance, postmarketing/
  229. Adverse reaction*.ti,ab.
  230. Adverse drug reaction*.ti,ab.
  231. drug toxicity/
  232. drug toxicity.ti,ab.
  233. Harm*.ti,ab.
  234. or/222-233
  235. 221 and 234
  236. case-control studies/
  237. retrospective studies/
  238. cohort studies/
  239. longitudinal studies/
  240. follow-up studies/
  241. prospective studies/
  242. Cross-Sectional Studies/
  243. cohort.ti,ab.
  244. longitudinal.ti,ab.
  245. follow up.ti,ab.
  246. followup.ti,ab.
  247. prospective*.ti,ab.
  248. retrospective*.ti,ab.
  249. comparison group*.ti,ab.
  250. control group*.ti,ab.
  251. observational.ti,ab.
  252. nonrandom*.ti,ab.
  253. database*.ti,ab.
  254. population*.ti,ab.
  255. cross sectional.ti,ab.
  256. or/236-255
  257. 235 and 256
  258. limit 257 to humans
  259. limit 257 to animals
  260. 259 not 258
  261. 257 not 260
  262. limit 261 to english language
  263. limit 262 to yr=”2005 -Current”
  264. 179 or 263
- Database: Cochrane Database of Systematic Reviews, CENTRAL and DARE
  Search Strategy:
  #1 “cardiovascular disease”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=1)
  #2 “cardiovascular diseases”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2)
  #3 “heart disease”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=3)
  #4 “heart diseases”:ti,ab,kw , from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=4)
  #5 Arrhythmia*:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=5)
  #6 Cardiomyopath*:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=6)
  #7 “Heart Arrest”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=7)
  #8 “Heart Failure”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8)
  #9 “Myocardial Ischemia”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=9)
  #10 “Ventricular Dysfunction”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=10)
  #11 “myocardial infarction”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=11)
  #12 “Coronary artery disease”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=12)
  #13 “heart attack”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=13)
  #14 “heart attacks”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=14)
  #15 “Ischemic heart disease”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=15)
  #16 “Vascular Diseases”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=16)
  #17 “Vascular Disease”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=17)
  #18 Aneurysm*:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=18)
  #19 “Arterial Occlusive”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=19)
  #20 Cerebrovascular:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20)
  #21 “Carotid Artery”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21)
  #22 stroke:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22)
  #23 “Diabetic Angiopathies”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23)
  #24 “Diabetic Angiopathy”:ti,ab,kw, from 2005 to 2012 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24)
  #25 Hypertension:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25)
  #26 “Peripheral Vascular”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=26)
  #27 “Peripheral Arterial”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=27)
  #28 Prehypertension:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28)
  #29 Hyperlipidemia*:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=29)
  #30 Hypercholesterolemia*:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=30)
  #31 “High cholesterol”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=31)
  #32 “elevated cholesterol”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=32)
  #33 “Abdominal Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=33)
  #34 “Bone Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=34)
  #35 “Breast Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=35)
  #36 Digestive near/2 Neoplasms:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=36)
  #37 endocrine near/2 Neoplasms:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=37)
  #38 “Eye Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=38)
  #39 Head near/3 Neoplasms:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=39)
  #40 neck near/3 Neoplasms:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=40)
  #41 “Hematologic Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=41)
  #42 “Nervous System Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=42)
  #43 “Pelvic Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=43)
  #44 “Skin Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=44)
  #45 “Soft Tissue Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=45)
  #46 “Splenic Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=46)
  #47 “Thoracic Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=47)
  #48 “Urogenital Neoplasms”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=48)
  #49 “Intestinal Polyps”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=49)
  #50 “lung cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=50)
  #51 “breast cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=51)
  #52 “colorectal cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=52)
  #53 “colon cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=53)
  #54 “prostate cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=54)
  #55 “gastric cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=55)
  #56 “stomach cancer”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=56)
  #57 “colorectal polyps”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=57)
  #58 “Colon polyps”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=58)
  #59 “Colonic polyps”:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=59)
  #60 adenomas:ti,ab,kw, from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=60)
  #61 (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54 OR #55 OR #56 OR #57 OR #58 OR #59 OR #60), from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=61)
  #62 (Calcium near/2 dietary):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=62)
  #63 (calcium next supplement*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=63)
  #64 “folic acid”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=64)
  #65 folate:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=65)
  #66 Thiamine:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=66)
  #67 thiamin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=67)
  #68 “Vitamin B 1”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=68)
  #69 “vitamin b1”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=69)
  #70 Aneurin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=70)
  #71 Riboflavin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=71)
  #72 “Vitamin B 2”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=72)
  #73 “Vitamin B2”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=73)
  #74 “Vitamin B 6”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=74)
  #75 “Vitamin B6”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=75)
  #76 Pyridoxine:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=76)
  #77 “Vitamin B 12”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=77)
  #78 “Vitamin B12”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=78)
  #79 Cobamides:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=79)
  #80 Hydroxocobalamin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=80)
  #81 Cobalamin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=81)
  #82 Cyanocobalamin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=82)
  #83 “Vitamin D”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=83)
  #84 Cholecalciferol:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=84)
  #85 Dihydroxycholecalciferol*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=85)
  #86 Calcitriol:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=86)
  #87 Ergocalciferol*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=87)
  #88 “Vitamin E”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=88)
  #89 Tocopherol*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=89)
  #90 Tocotrienol*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=90)
  #91 “Ascorbic acid”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=91)
  #92 “Vitamin C”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=92)
  #93 ascorbate:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=93)
  #94 “Vitamin A”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=94)
  #95 “beta carotene”:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=95)
  #96 Retinol:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=96)
  #97 (iron near/2 dietary):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=97)
  #98 (iron next supplement*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=98)
  #99 zinc:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=99)
  #100 Magnesium:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=100)
  #101 Niacin:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=101)
  #102 (Nicotinic near/2 acid*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=102)
  #103 Selenium:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=103)
  #104 (vitamin* near/2 dietary):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=104)
  #105 (vitamin* near/2 supplement*):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=105)
  #106 Multivitamin*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=106)
  #107 multimineral*:ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=107)
  #108 (#62 OR #63 OR #64 OR #65 OR #66 OR #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 OR #78 OR #79 OR #80 OR #81 OR #82 OR #83 OR #84 OR #85 OR #86 OR #87 OR #88 OR #89 OR #90 OR #91 OR #92 OR #93 OR #94 OR #95 OR #96 OR #97 OR #98 OR #99 OR #100 OR #101 OR #102 OR #103 OR #104 OR #105 OR #106 OR #107) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=108)
  #109 (#61 AND #108), from 2005 to 2013 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=109)
- Database: EMBASE
  Search Strategy:
  ‘calcium intake’:de OR ‘folic acid’:de OR ‘thiamine’:de OR ‘thiamine phosphate’:de OR ‘thiamine triphosphate’:de OR ‘riboflavin’:de OR ‘pyridoxine’:de OR ‘cobamamide’:de OR ‘cyanocobalamin’:de OR ‘hydroxocobalamin’:de OR ‘vitamin d’:de AND r AND ‘colecalciferol’:de OR ‘dihydroxycolecalciferol’:de OR ‘calcitriol’:de OR ‘ergocalciferol’:de OR ‘alpha tocopherol’:de OR ‘tocopherol’:de OR ‘alpha tocotrienol’:de OR ‘ascorbic acid’:de OR ‘beta carotene’:de OR ‘retinol’:de OR ‘iron intake’:de OR ‘zinc’:de OR ‘magnesium’:de OR ‘magnesium derivative’:de OR ‘nicotinic acid’:de OR ‘selenium’:de OR ‘selenium derivative’:de OR ‘vitamin’:de OR ‘multivitamin’:de OR ‘ferrous sulfate plus multivitamin’:de OR ‘mineral’:de AND (‘cardiovascular disease’:de OR ‘heart disease’:de OR ‘heart arrhythmia’/exp OR ‘cardiomyopathy’/exp OR ‘heart failure’/exp OR ‘heart muscle ischemia’:de OR ‘heart infarction’/exp OR ‘coronary artery disease’:de OR ‘vascular disease’:de OR ‘aneurysm’/exp OR ‘peripheral occlusive artery disease’/exp OR ‘cerebrovascular disease’:de OR ‘carotid artery disease’/exp OR ‘stroke’:de OR ‘diabetic angiopathy’/exp OR ‘hypertension’/exp OR ‘peripheral vascular disease’:de OR ‘peripheral occlusive artery disease’:de OR ‘hyperlipidemia’/exp OR ‘neoplasm’:de OR ‘neoplasms subdivided by anatomical site’/exp OR ‘intestine polyp’/exp OR ‘adenomatous polyp’:de) AND (‘randomized controlled trial’:de OR ‘randomized controlled trial (topic)’:de OR ‘controlled clinical trial’:de OR ‘controlled clinical trial (topic)’:de OR ‘meta analysis’:de OR ‘meta analysis (topic)’:de OR ‘randomization’:de OR ‘double blind procedure’:de OR ‘single blind procedure’:de OR ‘placebo’:de OR ‘systematic review’:de OR ‘systematic review (topic)’:de) AND [humans]/lim AND [english]/lim AND [embase]/lim AND [2005-2013]/py ‘calcium intake’:de OR ‘folic acid’:de OR ‘vitamin d’:de OR ‘colecalciferol’:de OR ‘dihydroxycolecalciferol’:de OR ‘calcitriol’:de OR ‘ergocalciferol’:de OR ‘alpha tocopherol’:de OR ‘tocopherol’:de OR ‘alpha tocotrienol’:de OR ‘beta carotene’:de OR ‘retinol’:de OR ‘iron intake’:de OR ‘selenium’:de OR ‘selenium derivative’:de OR ‘vitamin’:de OR ‘multivitamin’:de OR ‘ferrous sulfate plus multivitamin’:de OR ‘mineral’:de AND (‘safety’:de OR ‘adverse drug reaction’/exp OR ‘postmarketing surveillance’:de OR ‘drug surveillance program’:de OR ‘drug toxicity’:de) AND (‘case control study’:de OR ‘population based case control study’:de OR ‘retrospective study’:de OR ‘cohort analysis’:de OR ‘longitudinal study’:de OR ‘follow up’:de OR ‘prospective study’:de OR ‘cross-sectional study’:de OR ‘control group’:de OR ‘observational study’:de) AND [humans]/lim AND [english]/lim AND [embase]/lim AND [2005-2013]/py

Appendix B Figure 1 Literature Flow Diagram

Abbreviation: RCT = randomized, controlled trial.

Figure 4 is a flow chart that summarizes the search and selection of articles. There were 17,369 citations identified by searching MEDLINE, PsycInfo, Cochrane Center Register of Controlled Trials, and Cumulative Index to Nursing and Allied Health Literature. An additional 257 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 12,766 unique citations were screened at the title/abstract stage. The full text of 277 citations were examined for inclusion for one or more of the four Key Questions. The following number of articles were included for Key Question 1 (n=11), Key Question 2 (n=6), Key Question 3 (n=82), and Key Question 4 (n=55). Reasons for excluding the other articles are available in Appendix D.

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Inclusion | Exclusion
Populations | Efficacy (KQs 1, 3): Community-dwelling adults (age ≥18 years) without chronic disease and without nutritional deficiencies. Harms (KQs 2, 4): Community-dwelling adults and children (any age) without chronic disease. | Nonhuman populations; populations that only/exclusively included pregnant women, infants, individuals with a particular chronic disease, individuals receiving supplements as treatment for chronic disease (e.g., cancer, cardiovascular disease, HIV, end-stage renal disease, chronic kidney disease, tuberculosis), dialysis patients, individuals with clinical nutritional deficiencies, institutionalized individuals, organ transplant recipients, or hospitalized individuals.
Disease/ condition | KQs 1, 3: Primary prevention of cancer and cardiovascular disease; i.e., oncologic (breast, colorectal, lung, prostate, and gastric cancer; any other malignancy), cardiovascular (myocardial infarction, stroke). | Secondary and tertiary prevention or nutritional deficiencies.
Interventions | KQs 1, 2: Multivitamins defined as three or more vitamins and/or minerals without herbs, hormones, or drugs, each at a dose less than the UL as determined by the Food and Nutrition Board. KQ 3: Single nutrients and functionally related pairs each at a dose less than the UL as determined by the Food and Nutrition Board (i.e., calcium; folic acid; vitamins B_1_, B_2_, B_6_, B_12_, D, E, C, A; iron; zinc; magnesium; niacin; selenium; beta-carotene; calcium/vitamin D; calcium/magnesium; folic acid/vitamin B_12_; and folic acid/vitamin B_6_). KQ 4: Single nutrients and functionally related pairs each at a dose less than the UL as determined by the Food and Nutrition Board (i.e., calcium; folic acid; vitamins D, E, A; iron; selenium; beta-carotene; and calcium/vitamin D). | Did not address the use of supplements separately from dietary intake.
Comparisons | Not specified. | Not specified.
Outcomes | Efficacy (KQs 1, 3): Primary or secondary endpoint of disease or condition including mortality, will also accept study-specified surrogate outcomes (but must also report disease outcome). Harms (KQs 2, 4): Any harms (e.g., self-reported symptoms/adverse events, objective measurements such as blood or urine tests). | Efficacy (KQs 1, 3): Did not report disease or condition as primary or secondary outcome; precancerous outcomes (e.g., adenomas) without overt cancer outcomes. Harms (KQs 2, 4): Not specified.
Study designs | Efficacy (KQs 1, 3): Systematic reviews, RCTs. Harms (KQs 2, 4): RCTs or observational studies (including case reports and case series), postmarket surveillance data. | Efficacy (KQs 1, 3): Narrative reviews, nonrandomized studies. Harms (KQs 2, 4): Editorial, commentary, letter.

Abbreviations: KQ = key question; RCT = randomized, controlled trial; UL = upper intake level.

Appendix B Table 2 Quality Assessment Criteria

Design | U.S. Preventive Services Task Force quality rating criteria187 | National Institute for Health and Clinical Excellence methodology checklists45
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Study addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Reports percentage of each group (cases and controls) who participated in the study; - Comparison is made between participants and nonparticipants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Controls are clearly established from noncases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided
Randomized, controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept “blind” about treatment allocation; - Treatment and control groups are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Reports percentage of individuals or clusters recruited into each treatment arm of the study who dropped out before the study was completed; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Reports percentage of individuals or clusters recruited into each arm of the study who dropped out before the study was completed; - Comparison is made between full participants and those lost to followup, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided
Diagnostic accuracy studies | - Screening test relevant, available for primary care, and adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - Nature of the test being studied is clearly specified; - Test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - Test and gold standard are measured independently (blind) of each other; - Test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A prediagnosis is made and reported